# Future Research

1. Comparative effectiveness review methodologists will need to agree on a common data format and save all literature review decisions at the time of collection, as these data are much more easily accumulated over time than reconstructed later. At a minimum, the following elements are needed: data source (MEDLINE, EMBASE, PsycInfo, etc); source-specific identifier (e.g., PMID); study-specific identifier (e.g., LBD #1034); inclusion in final report for efficacy/effectiveness or AE analyses (or both); and title/abstract (if not in MEDLINE). Other information, e.g., inclusion after first stage screening and reason for exclusion from final study (if excluded) would be helpful as well.
2. The current model was built entirely upon MEDLINE classifications and is heavily reliant on their accuracy. Clearly, this characteristic would result in delaying the classification of newer articles. If reviews are being conducted every 2–3 years, this limitation would exclude only a small percentage of articles from the analysis (and leave them entirely for human review). However, if researchers wished to update reviews continuously (or monthly) and use citations from non-MEDLINE databases (such as EMBASE), absent or delayed MEDLINE indexing would render MEDLINE-only modeling inadequate. Further research on adding structured text characteristics to the statistical model would be helpful. Adding more (and presumably useful) features would improve accuracy as well. Other researchers have made extensive use of approaches based on “bag-of-words” when classifying documents for systematic reviews.14,20 The underlying hypothesis in these studies is that term frequencies will differ between relevant and irrelevant documents. For example, a relevant document might be more likely to contain the phrases “randomized trial” or “RCT”, whereas an irrelevant article might contain words such as “mouse” or “case-control.” One can then use statistical algorithms (such as GBM or SVM) to model relevance as a function of these many text features.
  A modified approach using both text- and MeSH-derived features could be helpful. For example, one could classify citations that lack MEDLINE indexing by determining whether their text features are most similar to articles that are predicted to be highly irrelevant or to those that are predicted to be highly relevant (among MEDLINE-indexed articles). Using these shared text features, the MeSH indexing could be leveraged to provide additional information to articles lacking indexing.
3. We will need to test our models on additional systematic reviews, surgical interventions, and on non-therapeutic applications; in addition, we will also test other commonly-used algorithms such as SVM. Additional research is needed before a particular updating approach can be recommended for practical use.
4. We will examine whether training data can be used across systematic review topics, if the underlying inclusion criteria are similar enough. This experiment has been attempted before but has not been applied to true updating.17 If this attempt is successful, we could vastly increase the volume of useful training data at our disposal.
5. We will need to streamline the process to make it production-ready and efficient. However, if classification decisions are readily available (see #1 above), the remainder of the process will not be labor-intensive; the key step will involve a clinical reviewer or research librarian spending 1–2 hours transforming the review’s search strategy into groups of terms (interventions, diagnostic tests, outcomes, etc.). We plan on developing a platform that would allow further data processing and modeling without human input. While predictions will still need to be evaluated by human reviewers, we plan on making this step time-neutral by providing samples of articles to be evaluated by comparative effectiveness review researchers as part of their normal workflow.
6. An active learning model could be adapted to perform in the updating context as well.15,20 For example, one could generate predictions for updated data and sample predicted relevant articles in a stratified fashion – that is, all articles in the updated search predicted to be highly relevant and a sample of indeterminate and lower-ranked citations. The model could then be re-run using these new training data to generate a new model. This effort would offer two advantages: (a) Newer models could account for changes in the literature; and (b) less reviewer time would be wasted because many of the reviewed articles would likely be relevant and require review.
7. Finally, we identified a small false negative rate associated with our approach. Using the references of included reports could reduce the false negative rate by identifying missed reports.