# Executive Summary

## Background

Comparative effectiveness reviews need to be updated to maintain their relevance, but these updates are often impeded by the need to screen thousands of citations to locate the 1–10 percent that are included in the final report (“relevant studies”). Such effort may match or exceed that involved in the original review. Prior studies have used machine learning methods to reduce the burden of comparative effectiveness review screening but have not formally simulated updating.

## Objective

We aimed to create a prototype system for assisting researchers with preparing formal updates of comparative effectiveness reviews. In this report, we describe a pilot study using reviewer decisions from two Agency for Healthcare Research and Quality (AHRQ)-sponsored comparative effectiveness reviews to empirically derive statistical models that predict article relevance to efficacy/effectiveness and adverse effect analyses; we then evaluated these models’ performance identifying relevant articles from the literature searches retrieved for the updated reviews. We based these statistical models on two algorithms: gradient boosting machine (GBM) and generalized linear models with convex penalties (GLMnet). Each model predicted an article’s relevance based on how its indexing terms described a select number of key concepts (such as publication type, intervention, and outcome). The key challenge was accounting for how search strategies, therapies, outcomes, research personnel, and overall objectives may have changed from the original to the updated study. In accord with an earlier study that noted that a high proportion of reviews underwent minor or major changes, both strategies underwent major revisions. To overcome such challenges (known as “concept drift” in other contexts), we represented specific drugs and outcomes as more abstract concepts such as “intervention” and “outcome,” with the hypothesis that this procedure would improve generalizability between time periods.

## Methods

We obtained PubMed citations retrieved by the AHRQ Southern California Evidence-based Practice Center (SCEPC) for two review topics (including the early and updated search results): the comparative effectiveness of interventions in preventing fractures in persons with osteoporosis (henceforth referred to as Low Bone Density or LBD) and the efficacy and comparative effectiveness of off-label uses of atypical antipsychotics (AAP). We considered articles to be “relevant” if they passed the second stage screening process and would have been considered for analyses of either efficacy/effectiveness or adverse effects (AEs). We did not exclude duplicates or studies included in prior meta-analyses because these studies were not excluded for intrinsic problems in study design or target population. We did not evaluate PubMed citations that had not yet been assigned MEDLINE indexing information (such as MeSH and Publication Type terms).

The body of articles included in the original LBD report (which we refer to as the training document literature) consisted of 14,700 citations retrieved for screening, of which 382 articles would have passed the second-stage screening—218 for efficacy/effectiveness and 279 for AEs (some articles included data on both efficacy/effectiveness and AEs). The LBD update corpus consisted of 7,051 retrieved articles (of which 127 would have passed the second-stage filter: 63 for efficacy/effectiveness and 92 for AEs). The AAP training corpus consisted of 1,307 retrieved articles, of which 98 articles would have passed the second stage filter-82 for efficacy and 91 for AEs. The AAP update consisted of 3,591 retrieved articles, of which 116 would have passed the second stage filter--101 for efficacy and 105 for AEs.

Prior study designs used all terms from the index and abstract (i.e., a “bag of words” approach) when modeling relevance. We hypothesized that a limited set of variables that were tightly related to certain key concepts would have substantial predictive power when used to model relevance. To test this hypothesis, we created a limited set of important predictor variables using key MEDLINE Subject Heading (MeSH) indexing terms and associated subheadings. Furthermore, transforming specific concepts such as “alendronate” and “fractures” into abstractions such as “intervention” and “outcome” should allow us to account for changes in outcomes and interventions over time. We selected these key terms by matching terms in the search strategies related to interventions and outcomes to MeSH terms within the MeSH database in a semi-automated fashion; in essence, our approach uses both statistical methods and domain knowledge (extracted from the search strategy) to make the modeling problem tractable. We then created a set of 92 binary explanatory variables representing whether intervention and outcome terms were present in the MEDLINE citation, and how they were described. In addition, we created a set of 29 binary explanatory variables related to article-level characteristics including demographic group (gender and age), treatment target (human, animal, in vitro study, and others), and publication type (review, randomized controlled trial [RCT], clinical trial, meta-analysis, and others), the presence of intervention or outcome terms (or synonyms) in the title, and whether “randomized controlled trial” or “meta-analysis” was mentioned in the title or abstract.

We created a series of eight models based on all combinations of two outcomes (inclusion in the final report for either efficacy or AEs), two statistical learning algorithms (GBM and GLMnet), and training data from two reviews (AAP and LBD). For each model, the inclusion outcome was made a function of extracted explanatory variables for each dataset (described above) using either GBM or GLMnet. GBM is a nonparametric tree-based approach while GLMnet is based on parameterized generalized linear models specifically created to produce sparser models by using convex penalties on the coefficients. We also created a “hybrid” approach that used the maximum prediction probability of relevance from both approaches (GBM- or GLMnet-based). This is equivalent to an approach that rejects only if both GBM- and GLMnet-based approaches reject. In addition, we evaluated how well GBM and GLMnet could predict inclusion for any outcome (efficacy/effectiveness or AEs) in a given review update (AAP or LBD).

To simulate performance in a true update, we generated models using the initial search results while being blind to the true update search results. We generated prediction scores for the updated search (2006–2010 literature for LBD and 2007–2010 for AAP—the test data) using the models described above. We generated a set of predicted relevant and irrelevant articles for the LBD and AAP updates that we compared against decisions that members of the EPC team generated independently. We then calculated performance on the updated results: sensitivity (percentage of relevant articles retrieved, also known as recall), positive predictive value (PPV—percentage of articles predicted to be relevant that were truly relevant, also known as precision), and the percentage of literature search screening that might have been avoided had this predictive model been used exclusively. We evaluated performance at multiple probability thresholds. There is no perfect threshold, because neither error minimization nor sensitivity maximization can be considered absolute goals; a strategy that rejected all articles might have an error rate of 1 percent (though all would be false negatives) while a strategy accepting all articles would have 100 percent sensitivity (though low PPV). To balance these objectives and conform to researcher preferences, we often judged primary results against a probability threshold of p≥0.02 because this threshold appeared to substantially reduce the error rate while preserving sensitivity. However, we also derived sensitivity-maximizing thresholds based on performance in the original AAP and LBD studies. We also evaluated the performance of these statistical approaches (GLMnet and GBM) by comparing their receiver operating characteristic (ROC) curves visually and via a nonparametric approach described in DeLong and colleagues.

## Results

There were substantial and statistically significant differences in the means of key variables between the original and updated searches, and between categories of each search (excluded, included in efficacy analysis, included in AE analysis, and included in both analyses). These differences suggest that combinations of variables could be used to distinguish between relevant and irrelevant studies; however, the design of the search differed between the update and original searches, which made modeling more difficult.

Model performance differed slightly between the three approaches (GBM, GLMnet, and hybrid), although GLMnet performed slightly better overall. Results below refer to GLMnet. For efficacy analyses, performance in predicting relevant articles was similarly strong for both the AAP and LBD comparative effectiveness reviews. The vast majority of irrelevant citations were assigned relevance probabilities of less than 0.02. The GLMnet approach yielded a sensitivity of 0.921 and PPV of 0.185 when predicting articles relevant to the AAP efficacy update. In considering articles relevant to efficacy for the LBD update, GLMnet model achieved sensitivity of 0.905 and PPV of 0.102 (using the p≥0.02 threshold).

For the AE analyses, performance in predicting relevant articles was strong for AAP but not for LBD. In the AAP analysis, the GLMnet model achieved sensitivity for AE-relevant articles of 0.981 and PPV of 0.09 at a threshold of p≥0.02. However, for the LBD study, the GLMnet-based model was able to predict AE-relevant articles with a substantially reduced sensitivity (0.685) for a similar PPV (0.116). When we analyzed articles missed for the AE analysis, we noted that there were relatively few relevant large observational studies (cohort and case-control studies) in the original review. As a result, the model assigned lower probabilities to observational studies in the LBD update as well. However, observational studies were more important in the update because the researchers updating the systematic review focused on several newly identified AEs that were largely studied in cohort and case-control studies.

We also simulated (using GLMnet) a process for estimating potential workload reductions while maximizing sensitivity in identifying all articles relevant to AE and efficacy analyses. Sensitivity and PPV for a particular threshold were determined by selecting articles if the maximum predicted relevance for either outcome (efficacy or AE) exceeded the threshold. For the AAP study, the GLMnet-based model yielded projected sensitivity exceeding 0.99 (115/116 true positives) while the proportion of title/abstract screening saved was 55.4 percent or 1990/3591 articles. The GLMnet-based model produced perfect sensitivity when applied to the LBD update and decreased the projected article screening burden from 7,051 to 2,597 (63.2%). The GLMnet method seemed to perform slightly better than GBM in this context. The AUC for the GLMnet method (in the AAP study) was 0.943 (95% CI: 0.927 to 0.960) versus 0.925 (95% CI: 0.899 to 0.950) with GBM. The p-value for null hypothesis of equality was 0.007. Similarly, the AUC for the GLMnet method (in the LBD study) was 0.954 (95% CI: 0.943 to 0.965) versus 0.947 (95% CI: 0.933 to 0.961) for GBM. In the LBD study, p-value for null hypothesis of equality was 0.06. Both results suggest that the ROC curves differed between the two studies; in addition, GLMnet seems to perform somewhat better than GBM visually as well. Still, it would be difficult to establish GLMnet’s superiority (to GBM, SVM, or other algorithms) in this context (comparative effectiveness reviewing updating) without substantial additional research.

The searchers updating the systematic review independently evaluated articles in the update that were included in the final reports but were assigned relatively low probability scores (p≤0.02) by the statistical classifiers. There were 29 false negatives at a threshold of p≤0.02 from both the LBD and AAP updates; nearly all were articles that were not tagged as randomized trials by MEDLINE, and 26 were from the LBD update.

## Conclusions

In this report we utilized the large numbers of previously screened documents from two comparative effectiveness reviews to develop models that predicted whether citations retrieved for updated searches would have met final inclusion criteria. We tested several approaches based on the GBM and GLMnet statistical methods. Our approach achieved its best performance predicting relevance for efficacy/effectiveness articles; it performed worse when predicting articles relevant to the AE analysis for the LBD update. However, we estimated that these algorithms reduced (simulated) workload associated with screening updated search results by more than 50 percent with minimal or no loss of relevant articles. Furthermore, the researchers might have been able to retrieve the one excluded article (from the AAP update) because it was referenced in a relevant article and would plausibly have been caught using the researchers’ analyses of references accepted in the final reports. Based on the slight differences in model performance between the GBM, GLMnet, and hybrid approaches, improving identification of RCTs and refining methods for correcting differences between the original and updated reviews may be more important than algorithm selection in future research.

Future research is needed on methods for reducing the likelihood of false negatives further (thus reducing the tradeoff between missed articles and workload reductions). Promising methods include incorporating active learning approaches and using text features extracted from the title and abstract to improve capture of study design details, such as RCT design or meta-analysis. We will also need to test this method with other comparative effectiveness review topics. If future work validates these preliminary findings more broadly, we hope to integrate a more refined system into the workflow of comparative effectiveness review researchers. Additional research refining this system, expanding its scope, and comparing it to other methods could allow researchers to select an optimal machine learning method for updating their reviews.