# Acknowledgments

We would like to thank Roberta Shanman for the literature searches that were provided for the comparative effectiveness reviews. We would also like to thank Margaret Maglione, Martha Timmer, Elizabeth Roth, and Tanja Perry for their assistance with the data collection.