# Discussion

We created a prototype machine learning system that is designed to reduce the workload associated with comparative effectiveness review updating. Our system first extracted domain knowledge and thousands of previously classified documents from two comparative effectiveness reviews (LBD and AAP), and then modeled article relevance (i.e., inclusion in the final updated review) using several approaches based on the GBM and GLMnet statistical methods. In two simulated comparative effectiveness review updates, our approach achieved its best performance predicting relevance for efficacy/effectiveness articles; it performed worse when predicting articles relevant to the AE analysis for the LBD update. However, we estimated that these algorithms could reduce workload associated with screening updated search results for relevant efficacy/effectiveness and AE articles by more than 50 percent with minimal or no loss of relevant articles. Based on the slight differences in model performance between the GBM, GLMnet, and hybrid approaches, improving identification of RCTs and refining methods for correcting differences between the original and updated reviews may be more important than algorithm selection in future research.

## Evaluating Model Performance

Performance was similar when screening AAP citations for those relevant to efficacy/effectiveness and AE analyses. However, in the LBD analysis, we achieved substantially higher PPV for the same levels of sensitivity when predicting whether citations were relevant for the efficacy/effectiveness analyses as opposed to the AE analysis. Prior work has not focused heavily on AEs, so the benchmark is unclear here. However, we speculate that many of these false negatives (and the consequent poorer performance on the LBD study) can be attributed to the changed criteria for relevant AE citations. In the original LBD review, most of the articles relevant to AEs were RCTs because epidemiologic studies and retrospective database analyses are difficult to conduct prior to widespread use. Therefore, relevant citations in the original data set consisted (almost entirely) of RCTs; this would not have presented a problem if researchers only wanted RCTs in the update. However, the paucity of relevant non-RCT studies in the original data probably limited the ability of the model to efficiently retrieve relevant non-RCT studies. In addition, key included outcomes may be present in the full text, and yet not mentioned in the abstract or MeSH indexing terms. For example, in the LBD study, the key outcome was fracture prevention. However, often the articles mentioned just bone density in the abstract, while fractures were a secondary outcome described in the full text. As a result, we assigned a number of articles to the intermediate range because both relevant and irrelevant articles were frequently indexed under bone density. Such data extraction errors were unrelated to improper feature encoding, and might only be resolved by analyzing the full-text of these articles.

Our results concur with prior attempts at using machine learning to facilitate systematic review data collection; those studies used manually classified citations to predict inclusion in unclassified studies.14,15,20,21 These efforts were met with substantial success, particularly an active learning model, which achieved 50 percent workload reductions and 100 percent sensitivity. 20 Previous studies used all indexing and text terms when employing statistical algorithms to classify documents.14,20 The advantage of the prior approach is that little or no upfront investment is required outside of collecting an original data set. For a de novo search, removing upfront workload offers some advantages.

In contrast to prior studies, we adopted a more parsimonious approach that focused on a few key terms related to study design characteristics (publication type, demographic groups, and statistical design), intervention-specific characteristics, and outcome-specific characteristics. For many comparative effectiveness review updates, research librarians have already invested substantial time in creating optimal search strategies; we leveraged this effort using a prototype that parses previously created search strategies in a semi-automated fashion to locate key indexing terms. Furthermore, the vast majority of work was involved in creating the training data, which had already been completed. Therefore, the additional cost of making explanatory variables specific to each review was small when performing this simulated comparative effectiveness review update.

Furthermore, our algorithms explicitly dealt with updating, which afforded us far more initial training data than active learning models. However, our approach needed to surmount several new challenges because we needed to predict updated citations even though the literature was different, the reviewers changed, the search strategies changed, and (possibly) some of the underlying goals changed. Our approach achieved some success in combating data changes over time (known as concept drift in other applications).21,27,28,30,31 Achieving similar levels of success suggests benefits to an approach incorporating domain-specific knowledge about key interventions and outcomes. However, these algorithms also assigned moderately low relevance probabilities to numerous non-RCT articles relevant to AEs, suggesting that this approach cannot mitigate all issues related to concept drift. This suggests some role for an active learning approach that classifies a small number of update articles to maximize accuracy on the update.15,31 In addition, this approach allows us to separate efficacy/effectiveness and AE analyses; although most comparative effectiveness reviews do not separate these analyses, independent filtering mechanisms may be of interest to other researchers.

## Workload Reductions

For researchers seeking both AE and efficacy-relevant citations, we were able to remove approximately 50 percent of articles with loss of 1/116 articles for AAP and 0/127 articles of LBD. Clearly the false positive rate is high (~50%) but this process still could provide substantial value to researchers. One potential problem is that researchers conducting systematic reviews and comparative effectiveness reviews aim for 100 percent sensitivity; despite the high sensitivity rates achieved, the loss of one article suggests that researchers will have to make some tradeoffs between sensitivity and efficiency as it will be difficult to guarantee 100 percent sensitivity without excessively high false positive rates. On the other hand, it is unclear whether human reviewers can guarantee perfect sensitivity using current processes. In addition, other methods (such as reference mining) can be used to raise sensitivity further. In this case, the missed reference might have been found by searching among references for included articles.

Our results also suggest possible improvements as well. The classifier’s false negatives were more related to indexing variability than to model development. This observation suggests that capturing additional key variables might be more helpful than further statistical development. One method of doing so would be to use text features to improve capture of study design details, such as RCT design or meta-analysis. We used limited text features in generating predictions, but we anticipate that adding features from the entire text would be helpful, much as other machine learning document classification systems have done. In addition, the GLMnet model performed well with a limited number of training examples (1,307) for AAP suggesting that this method could be implemented within an active learning framework,15,20 and thus might be used to facilitate de novo reviews as well.

## Implication for EPC Processes

The results we present (along with previous work in document classification) show that workload associated with updating could be substantially reduced if earlier classification decisions were used to reduce the workload involved in screening articles. We estimated that roughly 50 percent of title/abstract screening might be rendered unnecessary using a predictive model to reduce the screening burden. However, several outstanding issues need to be resolved prior to making these tools widely available.

First, the classifier relied on having complete data (database identifier, decision regarding relevance to efficacy/effectiveness analyses, decision regarding relevance to AE analysis). If such data were not fully compiled in the initial report, creating a machine learning model would be unlikely to be cost-effective as excessive effort would be required to format the data properly.

Second, although our statistical model relied on dozens of citation characteristics, it was very sensitive to MEDLINE’s publication type field and MEDLINE indexing generally. NLM validates MEDLINE indexing against its own internal criteria and is responsive to re-indexing requests.46 However, NLM’s criteria did not match our criteria perfectly, which made model predictions less accurate. Several authors associated with the EPC group independently assessed false negatives (relevant citations that the model assigned a low probability of inclusion); typically, the low prediction probabilities for these included articles were due to problematic MEDLINE indexing of the publication type field. If such discrepancies could be accounted for, our other encouraging results suggest that this document classification prototype could be used to improve the efficiency of comparative effectiveness review updating. To that end, we are developing techniques for extracting information from the text to allow for greater consistency in determining the publication type (from our perspective) and other variables independent of MEDLINE indexing.

Third, predicting performance on update data using original data is imperfect thus far. While there was minimal performance declines in some cases (inclusion in any analysis), using identical thresholds in an update would have reduced sensitivity in other cases (inclusion in LBD effectiveness/efficacy analyses). Further testing on additional topics should allow us to provide researchers with better information regarding projected performance.

Finally, these systems currently work only with fully indexed PubMed citations. One mitigating factor is that the vast majority of relevant articles are located in PubMed. As described in greater detail below, we plan to generalize this model to articles lacking MEDLINE indexing by developing additional text analysis tools.