# Conclusions

In this pilot study, we created a prototype system that classified PubMed literature search results from two simulated comparative effectiveness review updates. We achieved good performance on both updates using statistical models that were empirically derived from earlier review inclusion judgments as well as explanatory variables selected using domain knowledge. Additional research refining this system, expanding its scope, and comparing it to other methods could allow researchers to select optimal machine learning methods for updating their reviews frequently and efficiently.