# Abbreviations

AAP: Atypical antipsychotic drug
AE: Adverse effect
AHRQ: Agency for Healthcare Research and Quality
AUC: Area under the receiver operating curve
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
GBM: Gradient boosting machine
GLMnet: Generalized linear models with convex penalties
LBD: Low bone density
MeSH: Medical subject heading
PPV: Positive predictive value
ROC: Receiver operating characteristic
SCEPC: Southern California Evidence-based Practice Center
SVM: Support vector machines
UMLS: United Medical Language System