# Methods

The IOM report organized the standards into four chapters:

- Standards for Initiating an SR (consisting of 8 standards with 28 elements)
- Standards for Finding and Assessing Individual Studies (consisting of 6 standards with 30 elements)
- Standards for Synthesizing the Body of Evidence (consisting of 4 standards with 13 elements)
- Standards for Reporting an SR (consisting of 3 standards with 11 elements)

The following methods were employed to identify and resolve discrepancies between these 82 elements of the standards for SRs and the EPC Methods Guide and current EPC practice, acknowledging the latter two entities may be distinct. During an initial phase (phase 1), all EPC directors, in consultation with their staff, were requested to categorize each standard and element into one of three categories:

1. Currently practiced by EPC with little/no variation; no further discussion needed
2. Common EPC practice with some variations; some discussion needed before adoption
3. Uncommon EPC practice or with substantial variations; much discussion and/or more evidence needed before adoption.

The feedback from all EPCs was compiled and presented in May 2011 at the EPC directors’ meeting, along with an outline of the remaining steps in the process. The rationale for both adhering to the IOM standards and for a considered response prior to automatic adoption were also outlined in this presentation. Adherence would result in reducing variability of practice, increasing transparency, improving quality, and clarifying an authoritative source in response to criticisms. Reasons for a considered response were because standards were developed based on structured consensus with reference to empirical data only when available, standards may be infeasible to adapt, and methods may be changing as technologies evolve.

The second phase (phase 2) of the process focused on the standards or elements in either category 2 or 3 (above) where less than 80 percent of EPCs reported the element as common practice currently with little or no variation. Items in these categories were grouped into four topics loosely corresponding to the four chapters of the IOM standards. Work groups to address the following topics were formed, with representative participation across EPCs.

1. program policies or procedures,
2. protocol elements,
3. searching/screening/reporting biases, and
4. synthesis of evidence

The list of workgroup participants can be found in Appendix A. Each workgroup was tasked with evaluating these category 2 or 3 items according to current EPC methods guidance or procedural protocol, and determining an appropriate disposition. Teleconference meetings held over a period of 4 months were the primary forums of discussion on each assigned item. For each, the relevant current EPC guidance was identified, and the disposition collectively determined as either “agreement,” “agreement with modifications,” or “disagreement.” In the cases where modification was recommended, updates to the EPC methods guide, or improved adherence to the methods guidance were suggested.