# Introduction

The Institute of Medicine (IOM), the health arm of the National Academy of Sciences, was established to provide independent, objective science-based advice to policymakers, health professionals, the private sector, and the public with regards to health care. At the request of Congress, in an effort to address the lack of universally accepted standards and the variations in addressing conflicts of interest, appraisals of evidence, and the overall rigor of evaluations, an independent committee of 16 experts was appointed by the IOM and charged to assess potential methodological standards that would assure objective, transparent, and scientifically valid systematic reviews (SRs) of comparative effectiveness research (CER), and to recommend a set of methodological standards for developing and reporting such SRs. The resulting report on standards for SR was subsequently released in March 2011.

The committee defined a standard as “a process, action, or procedure that is deemed essential to producing scientifically valid, transparent, and reproducible results.”1 The IOM report includes 21 standards, with 82 distinct elements of performance (defined as essential components of the standards.) While acknowledging that the recommended standards and elements are provisional, pending better empirical evidence, they are based on current evidence, expert guidance, and thoughtful reasoning using an a priori set of criteria for assessment, and are therefore considered to be current “best practices.” In particular, the committee reviewed the published methods manuals of leading SR groups including the Agency for Healthcare Research and Quality (AHRQ), the Centre for Reviews and Dissemination (University of York, UK), and the Cochrane Collaboration. They additionally conferred with experts at the Drug Effectiveness Review Project, the Emergency Care Research Institute, the National Institute for Health and Clinical Excellence (UK), and several AHRQ Evidence-based Practice Centers (EPCs), to finalize the list of essential steps and considerations in the SR process. Members of several of the EPCs also served on the report committee as members, consultants or peer reviewers.

Following the release of the IOM standards, the EPC program established a process to comparatively examine the standards, and, more specifically, each of their elements of performance, with respect to general EPC practice and guidance. Many elements of performance in the IOM report are already intrinsic to the EPC program. Other elements lack supporting empirical data but possess an intuitive validity. Others are difficult to implement practically. The overarching agenda of this examination was to assess which elements should be adopted into EPC methods guidance; determine the best methods for implementing these changes, including dissemination and training; and lay out a process of evaluating adherence. Where standard recommendations are determined to require further empirical evidence, methods research should be conducted for validation and improvement. The present report describes and summarizes the collaborative process undertaken by the EPCs in evaluating the IOM standards, elements of performance, and the resulting conclusions.