# Acknowledgments

The authors gratefully acknowledge the contributions provided to this report by all participants in the EPC Workgroups on IOM Standards (see Appendix A), and all EPC investigators who provided the initial EPC response to the practice of the IOM Standards (see Appendix B).