# Discussion

While the standards and elements of performance laid out by the IOM committee on standards for SR are considered to be current “best practices”, the committee itself described them as “provisional, pending better empirical evidence about their scientific validity, feasibility, efficiency, and ultimate usefulness in healthcare decisionmaking.”1 This [underlined: acknowledgement] by the committee emphasizes the need for empiric testing of these recommendations. Many of the recommendations were based on theoretical principles and variable levels of empiric evidence without overall evaluation of the balance of benefits and required resources when implementing all recommendations, a task beyond the scope of the committee.

In general, this paper describes the high level of agreement between the EPC program and the IOM recommendations. As previously stated, of the 82 elements of performance within the IOM standards, 34 (41%) were identified for potential disagreement and further discussion. Of these 34, EPC workgroups generally agreed with the majority of these recommendations in principle. However, EPC workgroups identified three elements that they did not recommend routinely for the EPC program. One of these rare disagreements (IOM element 3.1.3: Use an independent librarian or other information specialist to peer review the search strategy) was due to concerns about whether the empiric evidence to support the recommendations outweighed concerns about the feasibility or burden. In this case, the EPC workgroup recommends further evaluation prior to routine implementation of the recommendation. Although the EPC workgroup disagreed with the recommended approach for implementing IOM element 2.7.1 (provide a public comment period for the protocol and publicly report on disposition of comments), they agreed on the underlying principle and suggest an alternative method for implementation. The final IOM element that the EPC workgroup did not recommend for routine adoption (IOM standard 3.2.5: Conduct a Web search) was because of lack of clarity and justification in the IOM standards.

The remaining 31 elements identified through phase 1 of this process were generally in agreement with current EPC guidance. Discussion by the workgroups identified areas where EPCs have tried to implement the recommended elements with variable success. Appendix B shows the directors’ responses to the initial survey, revealing a variation of practice among EPCs on a number of items. This lack of consistency highlights areas where greater clarity and specific instructions would be helpful to improve adherence to generally agreed upon principles. This report acknowledges the need for further research, where possible, in areas of uncertainty to inform best practice. The EPCs will use this evidence to determine appropriate trade-offs between empiric evidence and feasibility (limited resources) for all standards and elements for each particular task.1

Workgroup discussions focused on cohesion of recommended standards and the effects of implementing all recommended standards. As one example of this, the Program workgroup struggled with how to manage bias and conflicts of interest among those providing input into the review (IOM Standard: 2.4.2). However, this needs to be balanced with the need to ensure appropriate clinical expertise and to ensure opportunities for public input and comment.

This process identified areas for improved practice within the EPC program. It identified standards that are recommended in EPC methods guidance but not routinely practiced and require clarifications and greater efforts at ensuring consistent implementation through dissemination and training. Workgroups also identified standards which are already stated practice across EPCs but where the IOM standards highlight reasonable suggestions which could improve on existing practice and procedures. For example, discussion of Standard 2.8, which states that the protocol should be publicly available with the inclusion of any amendments, led to a more clearly defined criteria for protocol changes which qualify for an amendment. A revised protocol template inclusive of a table documenting protocol amendments will improve transparency of adherence to this standard.

As a summary of this exercise, across all workgroups, two major categories for further action were identified which would result in improved practice across EPCs. There were areas that workgroups determined would require additional research or development, and there were specific areas of EPC guidance that require updating.

Further research or development needed before adoption:

- Defining nonfinancial conflicts of interest with suggested frameworks for how they can be used to identify and reduce risk of bias
- Defining the major required protocol elements (or level of required detail) and those items requiring a protocol amendment
- Examining SR methods for considering heterogeneity of treatment effect for guiding the selection of subgroup factors (see conclusions of Workgroup 2 recommendations for action)
- Establishing evidentiary basis for Independent peer review, by librarian or information specialist, of search strategies
- Establishing best methods for identifying and assessing reporting bias
- Validating the benefit of searching citation indexes
- Validating that inclusion of non-English studies changes study conclusions

Update EPC guidance to:

- Clarify current EPC protocol instructions mandating that they:
  ○ describe the rationale for conducting each particular SR,
  ○ describe its potential contribution to the existing evidentiary base,
  ○ state how evidence will be summarized in a clinically relevant manner
- Include a minimum set of items to report in protocols (per the in-process PRISMA-P guidelines, see Workgroup 2 recommendations for action.)
- Use TEP to advise in cases where a significant portion of the literature may only be available in a regional database
- Document a priori decisions on the use of non-English studies, while allowing for ad hoc decisions which are fully documented in the Methods section
- Decide when to contact study authors (researchers) and how best to report this practice in the methods section of the review
- Conduct systematic approaches to ensure a reliable screening process when dual screening is not used
- Select an alternative practice (e.g., an independent reviewer checking abstracted data against full text) when dual, independent data abstraction is not done
- Implement strength of evidence assessment consistently, across EPCs, and in particular best methods for assessing reporting bias
- Develop a more detailed plan for conducting sensitivity analysis
- Identify and search for specific types of grey literature and to describe the value of each grey literature source for specific types of reviews
- Explain the circumstances requiring hand searching of journals and conference abstracts

Although not within the intended scope of the workgroup discussions, several workgroups made recommendations for the implementation of some elements. These are included here to inform future discussion:

- Implementation of newly defined standards for reducing risk of bias through nonfinancial conflicts of interest among the study team
- Review of role and responsibilities, and the establishment of a fair procedure for resolving discrepancies among review authors, those providing solicited input, and the AHRQ officer
- Implementation of methods for improving the accuracy/consistency of study selection
- Training and testing of screeners for accuracy
- Clarification in Methods section of circumstances under which researchers should be contacted

## Conclusion and Recommendations

This project has engaged the EPCs in a productive process of evaluation and response to the work of the IOM committee on SR standards. This paper describes the EPC experiences in implementing many of the IOM recommendations and the limitations they have experienced regarding lack of clear instructions or other difficulties in consistent implementation across many groups of systematic review investigators. This paper outlines resulting recommendations to conduct research to further validate certain of the IOM standards and elements, to update the EPC guidance where it was found lacking in detail or clarity, to conduct further work where the IOM standards lack sufficient detail, and to improve training of those conducting evidence reviews. This will provide a better framework for determining when the variation of practice among EPCs is a desirable thing, and when standards should be more consistently applied. Principally, this process has, and will, result in improvements in EPC practice, and has identified where further work is needed to provide scientific justification for these practices.