# Summary of Decisions and Protocol for Resolution in the Event of Difference of Opinion Between EPC Report Authors and AHRQ Officer

This summary has been incorporated into the EPC procedure guide.

1. EPCs are the authors of the report and should not write anything that they do not agree with. They should respond to all comments from the AE, TOO, reviewers, or AHRQ and if changes were not made, justify why.
2. Justifiable reasons for nonacceptance of a report by the AHRQ officer would include inconsistencies within a report, nonadherence to accepted Methods Guidance, inadequate justification or response to comments.
3. A common practice by AHRQ officers is to repeat comments that they feel particularly strongly about 2 or 3 times. To save time in the back-and-forth, the AHRQ officer should stratify comments by those that are critical to be changed from those that are helpful suggestions. Likewise, to save time, the EPC should provide a clear justification for why any changes are not made and perhaps schedule a call to discuss if necessary.
4. If there is continued disagreement about how to address the comments of the AE or TOO, the EPC should try to resolve the disagreement or uncertainty in a conference call with the AE and TOO.
5. If disagreement cannot be resolved with a conference call, the EPC should prepare a letter explaining the disagreement and send to the AE and TOO, who will review the letter before the TOO forwards it to the EPC Program Director.
6. The EPC Program may then request input from an unconflicted external content, statistical, or methods expert prior to making a determination. If no resolution can be made with third-party review, AHRQ will not prohibit publication and the EPC may publish with the appropriate disclaimer that is contained in Section H.1.b.2.B of the EPC contract.

If there is significant disagreement on the revisions requested, the EPC should schedule a comments call with the TOO and AE to discuss the requested changes within 1 week of receipt of the decision letter. If disagreement cannot be resolved with a conference call, the EPC should prepare a letter explaining the disagreement and send to the AE and TOO, who will review the letter before the TOO forwards it to the EPC Program Director. The EPC Program may then request input from an unconflicted external content, statistical, or methods expert prior to making a determination.