# Workgroups

EPC Workgroups on IOM Standards for SR:

Workgroup 1: Program

Leader/TOO: Stephanie Chang

Participants:

- Eric Bass (JHU)
- Stanley Ip (Tufts)
- Melissa McPheeters (Vanderbilt)
- Sydney Newberry (RAND)
- Susan Norris (Oregon)
- Margaret Piper (BCBS)
- Paul Shekelle (RAND)
- Meera Viswanathan (RTI)
- Evelyn Whitlock (Oregon)
- Michael White (UConn)
- Renee Wilson (JHU)

Workgroup 2: Protocol

Leader: David Moher and Stephanie Chang

TOO: Christine Chang

Participants:

- Nancy Berkman (RTI)
- Mark Helfand (Oregon)
- Joseph Lau (Tufts)
- Kathleen Lohr (RTI)
- Melissa McPheeters (Vanderbilt)
- Susan Norris (Oregon)
- Jodi Peters (Ottawa)
- Lisa Sarsany (BCBS)
- Jodi Segal (JHU)
- Larissa Shamseer (Ottawa)
- Paul Shekelle (RAND)
- Tom Trikalinos (Tufts)
- Evelyn Whitlock (Oregon)

Workgroup 3: Searching

Leader: Howard Balshem

TOO: Kim Wittenberg

Participants:

- Naomi Aronson (BCBS)
- Michelle Brasure (MN)
- Donna Dryden (Alberta)
- Bob Kane (Minnesota)
- Rose Relevo (OHSU)
- Gillian Sanders Schmidler (Duke)
- Paul Shekelle (RAND)
- Tom Trikalinos (Tufts)
- Michael White (CT)

Workgroup 4: Synthesis

Leader: Nancy Berkman

TOO: Bill Lawrence

Participants:

- Mohammed Ansari (Ottawa)
- Ethan Balk (Tufts)
- Brittany Burda (Oregon)
- Gerald Gartlehner (RTI)
- Lisa Hartling (Alberta)
- Bob Kane (Minnesota)
- Susan Norris (Oregon)
- Parminder Raina (McMaster)
- James Reston (ECRI)
- Gillian Sanders Schmidler (Duke)
- Sonal Singh (JHU)