# Results

Results are presented in five sections: (1) concordance between RCTs included in the Management of Infertility SR and in CT.gov; (2) studies identified from CT.gov as potentially eligible but not included in the Management of Infertility SR; (3) concordance between data from CT.gov and published studies for studies present in both sources; (4) effects of CT.gov results on SOE and review conclusions; and (5) person-hours required to generate these results.

## Concordance between RCTs Included in the Management of Infertility SR and in CT.gov

Twenty-four unique RCTs reported live birth as an outcome and were included for KQs 1, 2, and 4 in the Management of Infertility SR. The majority of these trials (n=22) were applicable to KQ 1. Of the 24 trials:

- 8 were matched to a CT.gov record by NCTID
- 3 were matched by other trial ID number
- 1 was matched by other criteria (i.e., study characteristics)
- 12 were not matched

All matched studies were confirmed by an investigator. Three preliminary matches based on “other criteria” were not confirmed by study investigators and are included in the 12 unmatched studies above.

Only one-third of the included trials were matched to a CT.gov record using the NCTID, the most reliable and readily applied matching variable. When using all available data, 50% (95% CI, 30 to 50%) of the eligible studies were matched to a CT.gov record.

## Studies Identified from CT.gov as Potentially Eligible but Not Included in the Management of Infertility SR

Using broad search criteria, we searched CT.gov for potentially eligible studies. The search yielded 858 registered studies. Of those, 376 were classified as “completed.” The 355 studies published from 2005 forward were reviewed by two study staff, and 94 were flagged as potentially eligible for the Management of Infertility SR, with relevance to KQs as follows: KQ1 = 14, KQ 2 = 1, KQ 3 = 69, KQ 4 = 1, KQ 5 = 3, KQ 6 = 1, and multiple KQs = 5.

Of the 16 studies potentially relevant to KQs 1, 2, or 4, 11 had been identified in the Management of Infertility SR search and included in the review. The other five studies were reviewed by an investigator; details are reported in the Table 1.

Table 1 Potentially eligible studies not included in the review

NCTID | Search Strategy Identifying Trial | CT.gov Completion Date | Classification
NCT01675843 | Both | March 2012 | Potentially eligible; no citation in PubMed
NCT01679574 | Both | January 2012 | Potentially eligible; no citation in PubMed
NCT01894074 | Broad | July 2015 | Potentially eligible, no citation in PubMed
NCT00220545 | Both | March 2006 | Identified in original review search but excluded at title-and-abstract screening stage. Full text reviewed and study included in Management of Infertility SR.
NCT01581359 | Both | May 2015 | Potentially eligible, no citation in PubMed

Only five potentially eligible studies were identified across the three KQs. Of these, two are recently completed trials (2015) and no journal publication was expected. Two trials with a combined sample size of 340 patients were completed more than 3 years ago, indicating potential publication bias. Both of these trials were applicable to KQ 1. One trial was excluded at the title-and-abstract screening phase of the review; upon review of the full text, the study was reclassified as eligible and included in the review.

## Concordance between Data from CT.gov and Published Studies for Studies Present in Both Sources

Study investigators participating in the transparency project abstracted data independently from CT.gov for the eight studies matched by the NCTID. These data were compared to data abstracted from published data by the Management of Infertility SR investigators.

Overall, there were no important differences in the [underlined: study characteristic] descriptions between the two sources. Details are described below:

- The KQ classification matched for all eight studies.
- The study design and number of study arms matched for all eight studies.
- Of five studies reporting the enrolled “n,” four were exact matches and one had a discrepancy in the estimated enrollment (326) versus the number enrolled (320). Three studies did not report the sample size in CT.gov and thus were classified as discrepant.
- Intervention descriptions were substantially concordant for all eight studies and thus were classified as matching.
- The analytic approach and any plans for subgroup analyses were not addressed in CT.gov for any of the studies. However, subgroup analyses were not reported in the published manuscripts for any of these trials.
- The funding sources were classified as matched for six studies. Two studies were classified as discrepant: one of these was classified as non-government/non-industry from CT.gov and as “not reported” from manuscript, and one was classified as non-government/non-industry from CT.gov and as government from the published manuscript.

Outcomes were compared at two levels: the outcomes [underlined: planned] from CT.gov to those reported in published manuscripts, and the results reported in CT.gov to those [underlined: reported] in published manuscripts.

- Planned outcomes: 11 outcomes were reported in both sources and classified as matched. Three outcomes reported as planned in CT.gov were not abstracted from manuscripts: quality of life,^7^ miscarriage,^8^ and live birth.^9^ In four studies, outcomes reported in published manuscripts were not described in CT.gov: live birth,^8,10^ miscarriage,^11^ multiple births,^11,12^ and surgical complications.^12^
- Only one^7^ of the eight trials reported results in CT.gov, and these results matched those reported in the manuscript for the single outcome present in both sources.

## Effects of CT.gov Results on Strength of Evidence

Overall, data from CT.gov had little impact on the SOE ratings. Using a threshold of 3 years since reported completion, only two completed trials were identified from CT.gov that did not have a matching journal publication. Both trials were applicable to KQ 1 and had a combined sample size of 340 patients. Thirty-one trials (5,718 patients), including one study reclassified as eligible (see Table 1), were included in the SOE rating for KQ 1, and thus these two “missing” trials are unlikely to have had a meaningful impact on study results. Similarly, there was little evidence of reporting bias, with only single mismatches for three different outcomes between planned outcomes in CT.gov and reported outcomes in published manuscripts.

## Person-Hours Required for Data Collection and Analysis

Overall, the project team devoted an estimated 74.5 hours to planning and conducting this study. Data by investigator versus staff are given in Table 2.

Table 2 Person-hours required, investigators versus staff

Name | Administrative (meetings, etc.) | Planning/designing | Running searches/abstracting data | Synthesizing data/writing | Total
Investigator | 7 | 9 | 10.75 | 7.75 | 34.5
EPC Staff | 23 | 0 | 14 | 3 | 40
Totals | 30 | 9 | 24.75 | 10.75 | 74.5