# References

1 Borenstein M, Hedges LV, Higgins JPT, . Publication Bias. Introduction to Meta-Analysis. John Wiley & Sons, Ltd; 2009:277–92.
2 Song F, Parekh S, Hooper L, . Dissemination and publication of research findings: an updated review of related biases. Health Technology Assessment. 2010 Feb;14(8):iii, ix–xi, 1–193. doi: 10.3310/hta14080. PMID: 20181324.20181324
3 Sterne JA, Sutton AJ, Ioannidis JP, . Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
4 Dwan K, Altman DG, Clarke M, . Evidence for the selective reporting of analyses and discrepancies in clinical trials: a systematic review of cohort studies of clinical trials. PLoS Med. 2014 Jun;11(6):e1001666. doi: 10.1371/journal.pmed.1001666. PMID: 24959719.24959719
5 Hartung DM, Zarin DA, Guise JM, . Reporting discrepancies between the ClinicalTrials.gov results database and peer-reviewed publications. Ann Intern Med. 2014 Apr 1;160(7):477–83. doi: 10.7326/M13-0480. PMID: 24687070.24687070
6 Agency for Healthcare Research and Quality (AHRQ). Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality. January 2014. Available at: http://www.effectivehealthcare.ahrq.gov/methodsguide.cfm. Accessed April 1, 2016.
7 Legro RS, Brzyski RG, Diamond MP, . Letrozole versus clomiphene for infertility in the polycystic ovary syndrome. N Engl J Med. 2014 Jul 10;371(2):119–29. doi: 10.1056/NEJMoa1313517. PMID: 25006718.25006718
8 Morin-Papunen L, Rantala AS, Unkila-Kallio L, . Metformin improves pregnancy and live-birth rates in women with polycystic ovary syndrome (PCOS): a multicenter, double-blind, placebo-controlled randomized trial. J Clin Endocrinol Metab. 2012 May;97(5):1492–500. doi: 10.1210/jc.2011-3061. PMID: 22419702.22419702
9 Palomba S, Falbo A, Carrillo L, . Metformin reduces risk of ovarian hyperstimulation syndrome in patients with polycystic ovary syndrome during gonadotropin-stimulated in vitro fertilization cycles: a randomized, controlled trial. Fertil Steril. 2011 Dec;96(6):1384–90.e4. doi: 10.1016/j.fertnstert.2011.09.020. PMID: 21982727.21982727
10 Abu Hashim H, El Rakhawy M, Abd Elaal I. Randomized comparison of superovulation with letrozole vs. clomiphene citrate in an IUI program for women with recently surgically treated minimal to mild endometriosis. Acta Obstet Gynecol Scand. 2012 Mar;91(3):338–45. doi: 10.1111/j.1600-0412.2011.01346.x. PMID: 22181973.22181973
11 Johnson NP, Stewart AW, Falkiner J, . PCOSMIC: a multi-centre randomized trial in women with PolyCystic Ovary Syndrome evaluating Metformin for Infertility with Clomiphene. Hum Reprod. 2010 Jul;25(7):1675–83. doi: 10.1093/humrep/deq100. PMID: 20435692.20435692
12 Palomba S, Falbo A, Battista L, . Laparoscopic ovarian diathermy vs clomiphene citrate plus metformin as second-line strategy for infertile anovulatory patients with polycystic ovary syndrome: a randomized controlled trial. Am J Obstet Gynecol. 2010 Jun;202(6):577.e1–8. doi: 10.1016/j.ajog.2009.11.042. PMID: 20096821.20096821