# Methods

## Scope and General Approach

We adopted a pragmatic approach, using methods that could be readily incorporated into future systematic reviews. To maintain feasibility while still applying our methods to a range of interventions, we included Key Question (KQ) 1, KQ 2, and KQ 4 from the Management of Infertility SR in this analysis. The KQs are listed below:

KQ 1 What are the comparative safety and effectiveness of available treatment strategies for women with [underlined: polycystic ovary syndrome (PCOS)] who are subfertile/infertile and who wish to become pregnant?
KQ 2 What are the comparative safety and effectiveness of available treatment strategies for women with [underlined: endometriosis] who are subfertile/infertile and who wish to become pregnant?
KQ 4 What are the comparative safety and effectiveness of available treatments for women with [underlined: tubal or peritoneal factors (e.g., pelvic adhesions)] who are subfertile/infertile and who wish to become pregnant?

## Searching CT.gov

We searched CT.gov for trials potentially applicable to the KQs with the assistance of our search librarian. Because CT.gov does not use MeSH-based search terms, we adapted the search strategies developed for the Management of Infertility SR to language appropriate for CT.gov. We conducted two searches—a broad search using the basic interface and a more specific search using the advanced interface in CT.gov. For the broad search, we searched for synonyms for infertility (infertility OR infertile OR subfertility OR subfertile OR sub-fertility OR sub-fertile) in the conditions field and limited our results to interventional studies. For the narrow search, we searched for the same synonyms for infertility in the broader search terms field and combined this with multiple, separate searches for each of the conditions of interest. This narrower search was also limited to interventional studies. Exact search strings used in both searches are given in Appendix A of the Management of Infertility SR.

Results of the two searches were imported into Excel.

## Matching Studies

We matched randomized controlled trials (RCTs) identified in CT.gov with those identified for the Management of Infertility SR at several levels.

First, we determined whether RCTs reporting a live birth outcome that were included in the Management of Infertility SR had a matching record in CT.gov. Matching was performed initially using the NCT identifier (NCTID). Our intention was to conduct this matching using a semi-automated process within the bibliographical database (EndNote^®^ Version X7; Thomson Reuters, Philadelphia, PA). This approach proved infeasible due to inconsistent assignment of NCTIDs to EndNote fields. Thus, all matching was accomplished by manual review. For unmatched studies, we conducted a secondary match using other trial registration numbers and then trial characteristics, including: condition, intervention, sample size, and author/investigator. Matching was performed initially for the broad CT.gov search. We then determined the proportion of matched studies that were not identified by the narrow CT.gov search.

Second, for matched studies (i.e., studies included in the Management of Infertility SR with a CT.gov record), we abstracted selected variables from the CT.gov record to determine whether key study design variables and reported outcomes matched information in the published manuscript. Variables abstracted were:

- Date of completion
- Number of study arms
- Intervention description
- Study design
- Outcomes measures and results prioritized in the Management of Infertility SR
- Analysis approach
- Subgroup analyses

Data from CT.gov were compared to published data. For each variable, the result was classified as: matching, discrepant, or possibly discrepant. Discrepant data were defined as cases where information was absent in one source but reported in another, or when the information given in the two sources was contradictory. Discrepancies were summarized narratively.

Third, we screened the unmatched CT.gov citations for potentially eligible completed trials. Eligibility criteria for each KQ are given in Table 1 of the Methods chapter of the main Management of Infertility SR. For potentially eligible studies identified from CT.gov, we used author names and intervention terms to search for a matching publication in PubMed. We classified studies into two groups: (1) potentially eligible completed study without a published manuscript; and (2) potentially eligible completed study with a matching published manuscript that was not identified in the systematic review search.

All matching was limited to studies published since the 2005 International Committee of Medical Journal Editors (ICMJE) policy requiring trial registration. Matching was performed initially by a research assistant, and reviewed by a study investigator. Team members involved in matching piloted the data collection forms and procedures to refine them before full use.

## Estimate of Person-Hours Required to Complete the Project

EPC staff routinely log the time spent working on projects using project-specific codes. Co-investigators do not log project time routinely. Therefore, our project coordinator sent regular queries to co-investigators asking for estimates of time spent (to nearest 15 minutes) completing project-specific tasks. These estimates were tracked in an Excel spreadsheet. We used the staff logs and co-investigator reports to estimate the total staff time and co-investigator time dedicated to completing project-related activities.

## Impact on Systematic Review Conclusions

Study conclusions will flow from the strength of evidence (SOE). We used the GRADE framework for evaluating SOE, a framework that includes assessment of risk of bias, consistency, precision, directness, and publication bias. The EPC risk of bias tool explicitly considers reporting bias. Therefore, risk of bias and publication bias are the domains most likely to be affected by supplemental data from CT.gov. In collaboration with authors of the Management of Infertility SR, we reviewed the SOE table to determine qualitatively whether study conclusions would change.