# Acknowledgments

The authors thank Gillian Sanders-Schmidler, Ph.D., and Evan Myers, M.D., M.P.H, for technical input and coordination with the associated Management of Infertility systematic review.