# Discussion

This substudy found that CT.gov has important limitations for identifying selective reporting. Only one-third of the studies included in the Management of Infertility SR were matched to a CT.gov record based on NCTID, and only one of those studies reported results in CT.gov. In addition, there were few discrepancies between planned outcomes reported in CT.gov and those reported in published manuscripts. A careful search and inspection of CT.gov for potentially eligible studies not identified by the review team yielded only two studies without a publication and one study incorrectly excluded at the title-and-abstract screening stage. These data had no impact on the SOE ratings or study conclusions, but required substantial person-hours to generate.

It is possible that CT.gov will mature into a more useful resource for the purpose of identifying selective reporting. Using data from CT.gov for the dates of trial registration compared to conduct of the study, it is clear that some studies were registered retrospectively. Prospective registration may yield more complete records and more informative data. However, it is likely that changes to CT.gov will be required for this database to serve as a useful source for identifying selective reporting.

At present, these results do not support the routine use of CT.gov to evaluate selective reporting. However, our study examined a small set of interventions for a single condition (infertility) and included a relatively small set of trials. Additional studies are needed before definitive conclusions can be drawn about the utility of CT.gov for detecting selective reporting. If changes to CT.gov were made to facilitate its use for this purpose, other resources could improve efficiency, including a customized EndNote filter for importing CT.gov results, a standard methodology to guide investigators, and additional data on the activities that can be reliably completed by study staff versus investigators.