# Results

The searches in MEDLINE® and Cochrane Database of Systematic Reviews identified 467 citations, of which 262 (56 percent) full-text articles were retrieved and evaluated for their eligibility. Included and excluded articles are listed in Appendix C and D. Of these, 181 reviews met the eligibility criteria (Figure 1); 19 (10 percent) evaluated cardiac implantable devices, 124 (69 percent) evaluated vascular devices, 16 (9 percent) evaluated orthopedic implants, 8 (4 percent) evaluated skin-replacement grafts, and 14 (8 percent) evaluated neurostimulators. Among eligible systematic reviews, 66 reviewed only randomized trials, 51 reviewed nonrandomized studies, 56 reviewed both, and 8 reviews did not explicitly mention the study designs of primary studies included.

Figure 1 Flow diagram of systematic review selection criteria

“Figure 1 is a diagram depicting the study flow. It summarizes the number of studies searched for and screened, with reasons given for their inclusion and exclusion. A keyword search in Medline, and Cochrane Systematic review databases yielded 467 abstracts. Excluded by abstract screening were 205. Articles selected for full-text review were 262. Of these, 81 were excluded after screening for the following reasons: narrative reviews, irrelevant topics, letters, and editorials. The remaining 181 articles were selected for data extraction. 19 unique reviews of cardiac implantable devices, 124 reviews of vascular interventional devices, 16 reviews of orthopedic implants, 8 reviews of skin replacement grafts, and 14 reviews of neurostimulator devices were ultimately included in the review.”

## Key Question 1 How are items such as literature searches, study selection, and results reported in published systematic reviews of implantable medical devices?

### Reporting of Literature Searches, Study Selection, and Results

This Key Question pertains to generic reporting aspects of reviews—items applicable to any systematic review including reviews of implantable medical devices. Overall results are presented in Table 2. Characteristics reported by nearly all (> 85 percent [median] of) reviews were search terms, years searched, inclusion or exclusion criteria, population at baseline, description of intervention, and types of studies included. These may be considered the core characteristics that are frequently reported within published systematic reviews of implantable medical devices. Among eligible reviews, infrequently reported items (less than 50 percent) were searches or inclusion of studies in more than one language (34 percent) and whether a grey literature search (search for unpublished literature) was performed (44 percent). No reviews reported on all 13 items relevant to search and selection criteria. Infrequently reported items for results included use of study flow diagram (44 percent) and a description of costs or cost-effectiveness of implantable medical devices (23 percent).

Table 2 Reporting of literature searches, study selection, and results in systematic reviews of implantable medical devices

Reporting Item | Total N=181 n (%)
Search
Search terms were described or referred to elsewhere | 165 (91)
Multiple databases were searched | 144 (79)
Years searched were described | 162 (89)
Multiple languages were included in search | 62 (34)
Authors explicitly stated searching for unpublished data | 80 (44)
Selection
Inclusion or exclusion criteria were stated | 175 (96)
Population at baseline was reported | 181 (100)
Interventions/exposures were described | 181 (100)
Comparators were described | 178 (98)
Outcomes were described | 178 (98)
Types of studies included were reported | 174 (96)
Number of studies included and excluded were reported | 116 (61)
Reasons for exclusion were described | 139 (76)
Results
A flow diagram for the number of studies included and excluded was used | 80 (44)
The total number of primary studies included across systematic reviews | 4288
Results were presented graphically | 117 (64)
Reviews that conducted a meta-analysis | 124 (69)
Costs or cost-effectiveness were described | 42(23)

#### Reporting of Items for Key Question 1 by Device Categories

The quality of reporting of literature searches, study selection, and results was generally uniform across device categories (Table 3). The items relevant to searches (done in three of five reporting items), study selection (in one of eight reporting items), and results (in three of five reporting items)were different across categories. These included performing searches in multiple databases, reporting of search dates, reporting of searches for unpublished data, and reporting of included and excluded studies. The differences across device categories for reporting items evaluating results included use of study flow diagram, graphical plots in meta-analyses, and description of costs (Table 3).

Table 3 Reporting of literature searches, study selection, and results in systematic reviews by device categories

Reporting Item | Vascular N=124 | Cardiac N=19 | Orthopedic N=16 | Neurostimulator N=14 | Skin Grafts N=8 | P-Value
Search
Search terms were described | 113 (91) | 17 (89) | 16 (100) | 12 (86) | 7 (88) | 0.12
Multiple databases were searched | 102 (82) | 17 (84) | 13 (81) | 5 (36) | 7 (89) | 0.003
Years searched were described | 89 (72) | 4 (20) | 11 (69) | 8 (57) | 6 (75) | 0.002
Multiple languages were included in search | 40 (32) | 9 (47) | 4 (25) | 4 (29) | 5 (63) | 0.39
Searching for unpublished data | 58 (47) | 15 (79) | 2 (13) | 2 (14) | 3 (38) | <0.001
Selection
Inclusion or exclusion criteria were stated | 119 (96) | 19 (100) | 15 (94) | 13 (93) | 8 (100) | 0.31
Population at baseline was reported | 124 (100) | 19 (100) | 12 (75) | 13 (93) | 8 (100) | 0.09
Interventions/exposures were described | 124 (100) | 19 (100) | 16 (100) | 13 (93) | 8 (100) | 0.10
Comparators were described | 117 (94) | 16 (84) | 14 (88) | 7 (50) | 7 (89) | 0.06
Outcomes were described | 124 (100) | 19 (100) | 16 (100) | 13 (93) | 8 (100) | 0.10
Types of studies included were reported | 117 (94) | 18 (95) | 16 (100) | 14 (100) | 8 (100) | 0.11
Studies included and excluded were reported | 84 (68) | 14 (74) | 10 (63) | 4 (29) | 4 (50) | 0.03
Reasons for exclusion were described | 98 (79) | 16 (84) | 11 (69) | 8 (57) | 6 (75) | 0.30
Results
A study flow diagram was used | 59 (48) | 13 (68) | 5 (31) | 1 (7) | 2 (25) | 0.008
The number of primary studies included | 2978 | 248 | 300 | 478 | 284 | NA
Reviews that conducted meta-analyses | 99 (80) | 15 (79) | 7 (44) | 3 (21) | 1 (13) | 0.06
Results were presented graphically (among those that conducted a meta-analysis) | 91 (73) | 15 (79) | 6 (38) | 3 (21) | 2 (25) | <0.001
Costs or cost-effectiveness were described | 19 (15) | 10 (58) | 5 (31) | 3 (21) | 6 (75) | 0.001

## Key Question 2 How do published systematic reviews of implantable medical devices report device- or operator-specific information?

### Reporting of Device-Specific Information

Device-specific information was infrequently reported (Table 4). Data on differences across devices were reported the most frequently, 47 percent of the time; about two thirds of reviews had no data differentiating within-device characteristics. A review would typically report data on devices (e.g., type of device and other device information) in a table describing their study and patient characteristics.

Table 4 Reporting of device- or operator-specific variables in systematic reviews of implantable medical devices

Reporting Area | Reporting Item | Total N=181 n (%)
Device-Specific Variables | Data on differences across device characteristics were discussed | 85 (47)
Device-Specific Variables | Data on differences within device characteristics were discussed | 64 (36)
Device-Specific Variables | Evolution of devices over time were discussed | 38 (21)
Operator-Specific Variables | Details of training/certification of provider were reported | 2 (1)
Operator-Specific Variables | Ramp-up in provider technique (i.e. learning curve) was discussed | 13 (7)
Operator-Specific Variables | Level of expertise of team/site were considered | 16 (9)
Operator-Specific Variables | Practitioner variability were discussed | 18 (10)
Operator-Specific Variables | Volume at sites effect were discussed | 14 (8)

Evolution of devices was discussed in the reviews as one of the factors that may have affected the outcome of procedures. For example, the discussion section of a review would attribute evolution in angioplasty and stent catheters as one of the factors to positively influence procedural outcomes in recent primary studies as compared with “older” studies. However, this information was seldom directly assessed or reported in the results section of a systematic review. Additional examples of device-specific information that appeared in the discussion section of systematic reviews are provided in Table 5.

Table 5 Examples of device-specific information that appeared in the discussion section of systematic reviews

Device-Specific Information
“These findings could be explained by the difference in drug-release kinetics, with the sirolimus-eluting stent releasing almost all the sirolimus in the first 6 months, while more than 80% of the paclitaxel remains unreleased from the polymer coating of the paclitaxel-eluting stent, potentially resulting in more prolonged endothelial dysfunction and delayed healing with the latter.” (Roukoz 2009 PMID 19486720)
Evolution of Devices Over Time
“However, it is premature to consider this conclusion definitive for several reasons. [Carotid artery stenting] technology and the technical expertise of operators currently performing the procedure are improving and are superior to those in the studies thus far reported.” (Paraskevas 2009 PMID 19698297)
“Since the last review was published 5 years ago and conducted over 9 years ago, new dressings may have been introduced and higher quality data published….It remains unclear which type of dressing is superior in terms of infection rate, healing quality, quality of life, and cost. It was difficult to compare moist and nonmoist dressings in this review because of the heterogeneity of the included articles.” (Voineskos 2009 PMID 19568092)
“Using meta-regression analysis, we found that the risks of CAS have decreased over time from 1993 to 2006. This may result from improvements in CAS technique, devices, or training and/or a better selection of CAS candidates over time. The development of devices to protect against embolism during the CAS procedure potentially constitutes an important advance.… However, there was significant heterogeneity across studies in this analysis. In fact, the apparent advantage of cerebral protection devices may be illusory. Indeed, the use of such protection devices has increased over time, and the apparent protective effect of those devices may have been confounded by advances in stenting technique and patient selection over time.” (Touze 2009 PMID 19892997)

CAS = carotid artery stenting, PMID = PubMed Identifier

### Reporting of Operator-Specific Information

Data on operator-specific information were rarely reported among included systematic reviews. When reported, they appeared most often in the discussion section. For example, only two reviews of vascular intervention category mentioned data regarding training or certification of the operator in their discussion section. The reviews described these as one of the factors influencing outcomes of the procedures. Table 6 lists selected examples of operator-specific information in systematic reviews of implantable medical devices.

Table 6 Examples of operator-specific information that appeared in the discussion section of systematic reviews

“The reason for the lower mortality rate in the DES group seen in our metaanalysis is unclear. It may be that DES, with known lower rates of restenosis, provides a true advantage over BMS.…An alternative explanation may relate to a procedural learning curve, as operators may have become more technically proficient at unprotected LMCA PCI by the time DES were favored.” (Pandya 2010 PMID 20630453)
“As a confounding variable, EPDs have been used more recently and therefore likely at a later stage of the operator's learning curve.” (Roffi 2009 PMID 19861324)
“Our analysis suggests that centers with an experience of more than 16 stent graft procedures had a significantly higher success rate and a lower rate of complications than less experienced centers.” (Xiong 2009 PMID 19660348)
“These cases were done by a widely varied population of surgeons with varying skill and widely varied surgical technique. It is difficult to standardize the ability of these many surgeons and apply the results to the general population of surgeons practicing today.” (Winegar 2010 PMID 20594011)
“Most centers which have reported, as shown in our reference list, on their experience of surgical correction of thoracic scoliosis with pedicle screws come from very experienced surgeons. Therefore, this literature review may not reflect the reality of what happens in less-experienced centers or with surgeons going through their learning curve.” (Hicks 2010 PMID 20473117)

BMS = bare-metal stents, DES = drug-eluting stents, EPD = embolic protection device, LMCA = left main coronary artery, PCI = percutaneous coronary intervention, PMID = PubMed Identifier

Reviews frequently discussed operators' learning curve and experience with device implantation as one of the factors that may be associated with temporal improvement in outcomes. Operator's learning curve or experience with device implantation was also discussed as a confounding variable that may have influenced outcomes. In order to allow sufficient experience with device implantation, some reviews restricted their eligibility criteria to studies that were published in later years. While most of the reviews discussed operators' experience and volume of the centers impacting outcome data, they rarely explored this variable in subgroup analyses.

### Reporting of Device- or Operator-Specific Information by Device Categories

#### Device-Specific Information

In particular, these two items—discussions on differences across devices and discussions within devices—varied significantly according to device category (Table 7). This information appeared most often in the tables describing study and patient characteristics or in the discussion section rather than in the results or analyses section.

Table 7 Reporting of device- or operator-specific variables and handling of heterogeneity in systematic reviews by device categories

Reporting Item | Vascular N=124 | Cardiac N=19 | Orthopedic N=16 | Neurostimulator N=14 | Skin Grafts N=8 | P-value
Device-Specific Variables
Differences across device characteristics were discussed | 68 (55) | 4 (21) | 9 (56) | 5 (36) | 2 (25) | 0.002
Differences within device characteristics were available | 48 (39) | 1 (5) | 9 (56) | 3 (21) | 4 (50) | 0.002
Evolution of devices over time were discussed | 27 (22) | 2 (10) | 5 (31) | 3 (21) | 1 (13) | 0.30
Operator-Specific Variables
Details of training/certification of operator were reported | 2 (2) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 1.00
Learning curve of operator was discussed | 12 (10) | 0 (0) | 1 (6) | 0 (0) | 0 (0) | 0.60
Level of expertise of team were considered | 12 (10) | 0 (0) | 5 (31) | 0 (0) | 0 (0) | 0.14
Practitioner variability were discussed | 16 (13) | 0 (0) | 2 (13) | 0 (0) | 0 (0) | 0.35
Volume at sites effect were discussed | 12 (10) | 0 (0) | 2 (13) | 0 (0) | 0 (0) | 0.47

##### Cardiac Implantable Devices

Differences across devices and within devices were rarely reported across reviews of cardiac implantable devices. When reported, one or more of the device-specific information such as device type, method of implant, pacing mode, and position of the electrode were reported under study characteristics. Data related to evolution of devices and their role on applicability of trial results were mostly mentioned in the discussion section.

##### Vascular Interventional Devices

Compared with other device categories, reviews of vascular interventional devices more frequently reported device type or generation of device in the results or discussion sections. Few reviews conducted exploratory subgroup analyses to evaluate their short- and long-term efficacy. In addition to the discussions related to evolution of devices to explain heterogeneity in outcomes, some reviews used evolution of devices to define their eligibility criteria by excluding trials or data relating to “older” trials.

##### Orthopedic Implants

In addition to the vascular interventional devices, systematic reviews of orthopedic implants reported device-specific information more frequently in the results or discussion sections than other device categories included. Details of devices were reported under study characteristics or the results section. Device-specific information included was one or more of the following: type of device, type of coating on the device number and location of device, surgical technique or approach, and extraction and insertion torque. Only one review conducted exploratory subgroup analyses of these variables to evaluate their effect on treatment. Evolution of devices was often mentioned in the discussion or conclusion sections to explain good outcome data and progress achieved in clinical management.

##### Skin Replacement Grafts

Compared with other device categories, differences across devices were less frequently reported across systematic reviews of skin-replacement grafts. When reported device-specific information were frequently available in the results under device characteristics section. Data on differences within devices were reported in one-half of the reviews. Data on skin-replacement grafts reported were type of skin grafts, composition, and bioabsorbability or if they required removal. Only one review mentioned evolution of devices as the objective to conduct a new systematic review.

##### Neurostimulator Devices

Compared with other device categories, differences across devices and within devices were less frequently reported across systematic reviews of neurostimulator devices. Information on differences within devices included stimulation parameter (frequency, intensity, and pulse width) and location of electrode placement across primary studies included. Data on differences across devices included only a mention of different types of devices without many details about different types of devices used across primary studies. Evolution of devices was discussed to explain differences in outcomes across primary studies included.

##### Operator-Specific Information

Only reviews of vascular interventional and orthopedic implants reported operator-specific information, while the other three categories did not (Table 7). Only two vascular interventional reviews mentioned training or certification of the operator. In both these reviews, data relevant to training or certification of the operator were reported in the discussion section as one of the factors influencing outcomes of the procedures.

Reviews of vascular interventional noted that some primary studies included data only from centers with experienced operators or excluded data from first few patients due to a significant learning curve observed early in the study. In order to mitigate the impact of technical refinements and the procedural learning curve, one review defined their eligibility criteria by including studies that were published in later years.

While most of the reviews discussed operators' experience and volume in the centers impacting outcome data, reviews rarely explored this variable in subgroup analyses. Reviews that included observational studies discussed practitioner variability as one of the biases inherent to observational data.

## Key Question 3 How is the reporting of heterogeneity handled in published systematic reviews of implantable medical devices?

Overall, items infrequently reported were the assessment or discussion of a sensitivity analysis (52 percent), and presentation of results by subgroups (51 percent) (Table 8). The majority of the meta-analyses utilized accepted methodologies (92 percent). The remaining 8 percent of the meta-analyses were performed by combining studies across designs. There were considerable differences across device categories for all reporting items of handling of heterogeneity (Table 9).

Table 8 Reporting of handling of heterogeneity in systematic reviews

Reporting Item | Total N=181^*^ n (%)
Handling of heterogeneity
Models for meta-analyses were reported | 123 (99)^*^
Meta-analyses used accepted methodology (e.g. studies grouped by design or similar interventions) | 114 (92)^*^
Heterogeneity was assessed or discussed | 139 (76)
Sensitivity analyses were assessed or discussed | 64 (52)
Results by subgroups were considered or quantified | 92 (51)

* Among 181 eligible systematic reviews, 124 conducted a meta-analysis

Table 9 Reporting of handling of heterogeneity in systematic reviews by device categories

Reporting Item | Vascular N=124 | Cardiac N=19 | Orthopedic N=16 | Neurostimulator N=14 | Skin Grafts N=8 | P-Value
Handling of heterogeneity
Models for meta-analyses were reported^*^ | 99 (100) | 15 (100) | 5 (71) | 3 (21) | 1 (100) | 0.03
Meta-analyses used accepted methodology (e.g. studies grouped by design)^*^ | 89 (90) | 15 (100) | 7 (44) | 3 (100) | 1 (100) | 0.62
Heterogeneity was assessed or discussed | 88 (71) | 8 (42) | 6 (38) | 1 (7) | 3 (38) | 0.10
Sensitivity analyses were assessed or discussed | 46 (46) | 12 (80) | 4 (57) | 1 (33) | 1 (100) | 0.008
Results by subgroups were considered or quantified | 65 (52) | 15 (75) | 8 (50) | 2 (14) | 2 (25) | 0.007

* Results were analyzed based on 124 reviews that conducted meta-analyses

## Key Question 4 What are the limitations and issues related to reporting of quality and generalizability in published systematic reviews of implantable medical devices?

### Reporting of Validity, Limitations, and Future Research Recommendations

Outcomes evaluated were mostly clinical outcomes (e.g., stroke, death) in 165 reviews (91 percent), surrogate outcomes (e.g., stent restenosis, wound epithelialization) in 66 reviews (36 percent), and 45 reviews (25 percent) evaluated both.

The items describing validity of primary studies—evaluation of risk of bias (43 percent), the assessment for publication bias (48 percent), and methodological quality using checklists (40 percent)—were infrequently reported among eligible systematic reviews. Study limitations were given in 96 percent of reviews; 82 percent provided specific future research recommendations (i.e., more than stating that future research is simply needed) (Table 10). The reporting of quality items varied significantly across device categories (Table 11). The overall strength of the body of evidence was assessed in only 33 reviews (18 percent); this quality item varied considerably across device categories (Table 11).

Table 10 Reporting of validity and generalizability information in systematic reviews of implantable medical devices

Reporting Item | Total N=181 n (%)
Validity
Risk of bias was assessed | 79 (43)
Publication bias was assessed^*^ | 59 (48)^*^
Quality items or checklists were applied and reported | 72 (40)
Discussion
Study limitations were described | 175 (96)
Overall strength of the body of evidence was assessed | 33 (18)
Specific future research recommendations were made | 149 (82)
Funding source was identified | 76 (42)
Authors' affiliation to industry was reported | 38 (21)

* Results were analyzed based on 124 reviews that conducted meta-analyses

Table 11 Reporting of validity and generalizability information in systematic reviews by device categories

Reporting Item | Vascular N=124 | Cardiac N=19 | Orthopedic N=16 | Neurostimulator N=14 | Skin Grafts N=8 | P-Value
Validity
Risk of bias was assessed | 56 (45) | 14 (74) | 6 (38) | 2 (14) | 5 (63) | 0.01
Publication bias was assessed^*^ | 45 (45) | 12 (73) | 3 (43) | 0 (0) | 0 (0) | 0.001
Quality items or checklists were applied and reported | 42 (34) | 13 (68) | 9 (56) | 3 (21) | 5 (63) | 0.02
Discussion
Study limitations were described | 116 (94) | 18 (95) | 15 (94) | 12 (86) | 8 (100) | 0.89
Overall strength of the body of evidence was assessed | 13 (11) | 2 (11) | 10 (63) | 4 (29) | 4 (50) | <0.001
Future research recommendations were made | 100 (81) | 14 (74) | 13 (81) | 13 (93) | 8 (100) | 0.66
Funding source was reported | 54 (44) | 12 (63) | 3 (19) | 5 (36) | 2 (25) | 0.04
Authors' affiliation to industry reported | 27 (22) | 5 (26) | 1 (6) | 4 (29) | 1 (13) | 0.33

* Results were analyzed based on 124 reviews that conducted meta-analyses

Identification of a specific funding source and reporting of author ties to industry were less frequently reported. Of the 76 reviews that declared funding source, 8 (11 percent) reported receiving industry funding, 16 (21 percent) reported receiving professional society funding, 21 (28) reported receiving government agency funding, and the remaining 31 (41 percent) reported receiving no funding. Reporting of specific funding varied significantly across device categories.

## Other Subgroup Analyses

### Comparison Between Reviews by Author Affiliation to Industry

Among 181 eligible systematic reviews, 38 reviews reported that authors conducting systematic reviews had affiliations to industry, and the remaining 143 reviews did not report this information (Appendix E, Table E1). Seventy-six reviews (42 percent) identified their funding.

Reviews that reported whether authors had industry affiliations were more likely to conduct a meta-analysis than reviews that did not disclose this information. For all other items, there were no differences across all reporting characteristics between reviews that reported authors' affiliations to industry and those that did not report this information, except for one item of conducting a meta-analysis.

### Comparison Between Reviews That Conducted a Meta-Analysis and Reviews That Did Not

Of the eligible systematic reviews, 124 conducted meta-analyses and the remaining 57 did not conduct a meta-analysis. Compared with reviews that conducted meta-analyses, reviews without meta-analyses were less likely to report whether searches were conducted in multiple databases or to look for unpublished data, explicitly report eligibility criteria or eligible studies, handling of heterogeneity, assessment of risk of bias, and specific future research recommendations (Appendix E, Table E2). Device and operator-specific characteristics across both subgroups were infrequently reported without any differences. Reviews without a meta-analysis were more likely to assess overall strength of evidence than reviews that conducted a meta-analysis.

### Comparison Between Reviews by Included Study Designs

Systematic reviews that included nonrandomized or observational study designs alone were less likely to identify unpublished data, or to conduct a meta-analysis, or to assess risk of bias. Data on differences within devices were less frequently reported in systematic reviews that included nonrandomized or observational studies alone. Similarly, quality items were less frequently reported in systematic reviews that included nonrandomized or observational studies alone. However, reviews that included nonrandomized or observational studies alone frequently reported specific future research recommendations (Appendix E, Table E3).

### Comparison Between Reviews by Type of Journal

Systematic reviews were analyzed by type of journal publication (general medical journals vs. specialty journals). Reviews published in specialty journals were less likely to identify unpublished data, conduct a meta-analysis, or assess risk of bias. However, there were no differences in reporting of device- or operator-specific data between reviews published in general medical journals and reviews published in specialty journals (Appendix E, Table E4).