# References

1 Muni NI, Gross TP, Boam AB, et al. Challenges in regulating breakthrough medical devices. Food Drug Law Journal. 2005;60(2):137-42. [pmid: 16097092].
2 Sedrakyan A, Marinac-Dabic D, Normand SL, et al. A framework for evidence evaluation and methodological issues in implantable device studies. Medical Care. Jun. 2010;48(6 Suppl):S121-S128. [pmid: 20421824].
3 McGauran N, Wieseler B, Kreis J, et al. Reporting bias in medical research - a narrative review. Trials. 2010;11:37. [pmid: 20388211].
4 Wieseler B, McGauran N. Reporting a systematic review. Chest. May. 2010;137(5):1240-46. [pmid: 20442127].
5 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. Ann Intern Med. Aug. 18. 2009;151(4):264-9. W64. [pmid: 19622511].
6 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. Apr. 19. 2000;283(15):2008-12. [pmid: 10789670].
7 Iorio A, Rocca A, Matino D, et al. Systematic reviews in the prognosis field: a critical appraisal of six core clinical journals. Cochrane Colloquium Abstracts Journal. 2010. http://www.imbi.uni-freiburg.de/OJS/cca/index.php?journal=cca&page=article&op=view&path%5B%5D=9558.
8 Tao KM, Li XQ, Zhou QH, et al. From QUOROM to PRISMA: a survey of high-impact medical journals' instructions to authors and a review of systematic reviews in anesthesia literature. PLoS One. 2011;6(11):e27611. [pmid: 22110690].
9 Boutron I, Moher D, Altman DG, et al. Extending the CONSORT statement to randomized trials of nonpharmacologic treatment: explanation and elaboration. Ann Intern Med. Feb. 19. 2008;148(4):295-309. [pmid: 18283207].
10 Boutron I, Moher D, Altman DG, et al. Methods and processes of the CONSORT Group: example of an extension for trials assessing nonpharmacologic treatments. Ann Intern Med. Feb. 19. 2008;148(4):W60-W66. [pmid: 18283201].
11 U.S. Department of Health and Human Services, Food and Drug Administration. Device Regulation and Guidance. 2011.
12 Implantable Medical Devices to 2014. 2595. Cleveland, Ohio. Freedonia Group. 2010.
13 Mahomed NN, Syed K, Sledge CB, et al. Improving the Postmarket Surveillance of Total Joint Arthroplasty Devices. Open Rheumatol J. 2008;2:7-12. [pmid: 19088864].
14 Margey R, McCann H, Blake G, et al. Contemporary management of and outcomes from cardiac device related infections. Europace. Jan. 2010;12(1):64-70. [pmid: 19910314].
15 Chung M, Balk EM, Ip S, et al. Reporting of Systematic Reviews of Micronutrients and Health: A Critical Appraisal. Nutrition Research Series. 2009;3. [pmid: 20734515].
16 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
17 Moher D, Tetzlaff J, Tricco AC, et al. Epidemiology and reporting characteristics of systematic reviews. PLoS Med. Mar. 27. 2007;4(3):e78. [pmid: 17388659].
18 Tricco AC, Tetzlaff J, Sampson M, et al. Few systematic reviews exist documenting the extent of bias: a systematic review. J Clin Epidemiol. May. 2008;61(5):422-34. [pmid: 18394534].
19 Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].