# Methods

We conducted a critical appraisal of the reporting of information in published systematic reviews and meta-analyses of implantable medical devices. We convened a Technical Expert Panel (TEP) to help identify device categories, refine Key Questions, and to comment on the methodological approach.

## Technical Expert Panel

The TEP, a group of eight national experts, was assembled to provide advice regarding the scope of the project. Members included private and public payers, industry representatives, an FDA representative, and the Task Order Officer from AHRQ. The Tufts EPC held teleconferences with the TEP and discussed the goals of the project. The TEP served strictly in an advisory capacity to identify the device categories (the most frequently used and expensive devices or those with broad implications for policy decisionmaking), to assist in the development of project's scope and Key Questions, and to define parameters for the methodology of the critical appraisal. After discussions with the TEP and AHRQ, the following five implantable medical device categories were selected for analyses: cardiac implantable devices (e.g., defibrillators), vascular interventional devices (e.g., stents), orthopedic implants (e.g., disc replacement), skin-replacement grafts (e.g., wound care products), and neurostimulators (e.g., deep brain neurostimulator).

## Literature Search

Critical appraisal of large numbers of implantable medical devices can be challenging since there are many published systematic reviews. Our objective was to evaluate approximately 200 recently published systematic reviews (deemed a priori as a feasible number). To reach this target, we limited our search to recent reviews as they are more likely to be relevant and adhere to reporting standards. Searches were conducted in MEDLINE® and the Cochrane Database of Systematic Reviews to identify systematic reviews published from January 2009 to December 2010, using key words for each of the five categories of implantable medical devices (Appendix A). No language restriction was applied.

Potentially relevant reviews were those articles in which the abstracts described searches or eligibility criteria for study identification or included terms such as “systematic,” “evidence,” “evidence-based,” “meta-analysis,” or “pooled analysis.” We included all eligible systematic reviews published within 2 years (from January 2009 to December 2010) for all topics. Our initial search identified a limited number of reviews for two of the five groups, namely skin-replacement grafts (2 reviews) and cardiac implantable defibrillators (9 reviews). In consultation with the Task Order Officer at AHRQ, we searched back to 2004 to identify additional eligible reviews related to these topics.

## Eligibility Criteria and Citation Screening

For the purpose of this report, a systematic review was defined as a publication that contained at least two of the following three components: a statement of the research questions (or aims or objectives), a description of the literature search, and a list of study-eligibility criteria. This approach was used in a previous empirical paper that considers these three components to identify a systematic review.15 During full-text screening, we noted that many published systematic reviews of implantable medical devices did not clearly report all three basic components. We did not contact authors for clarifications of these three components. Therefore, we used a liberal definition (at least two of the three components) in order to include a maximum number of current systematic reviews.

Since the objective was evaluation of reporting characteristics, we included reviews that were of any type of implantable device within each of the five categories and that reviewed a recent publication. For example, the cardiac implantable device category could include a review of a pacemaker, a review of a defibrillator, or a review of both a pacemaker and a defibrillator. We included systematic reviews of any design (randomized trials, nonrandomized comparative studies, or observational studies) and methodology for synthesis (qualitative or quantitative synthesis including meta-analyses of individual patient data). We included all reviews published within this time period, which could potentially include multiple reviews on the same topic or different reviews published by the same team of researchers. However, we did not include duplicate publications or similar reviews by the same team of researchers. We did not restrict our evaluation to any particular devices or uses of an implantable device for any particular conditions.

There were no specific sampling criteria per device category; this approach is reasonable because it reflects the proportion of relevant articles in the published literature. Though an even distribution of reviews across the five implantable medical device categories would be preferable, this could not be achieved because of a large number of articles reviewing vascular interventional devices, in particular stents. The TEP concurred with the approach of selection of reviews without specific sampling criteria, as our primary objective was to make an overall inference about devices.

We assessed titles and/or abstracts of citations identified from literature searches for potentially relevant systematic reviews. Reviewers with prior experience in conducting systematic reviews and data extractions participated in abstract and full-text article screening and data extraction. All participating reviewers had to have no conflict of interest and were required sign disclosure statements. The titles and/or abstracts were screened by one reviewer. Abstracts tagged “reject” by a reviewer were rescreened by a second reviewer. Full-text articles of abstracts that met screening criteria were retrieved and examined by two independent reviewers to confirm their eligibility according to predetermined criteria. All disagreements were resolved in consultation with a senior reviewer. The reasons for excluding systematic reviews (e.g., narrative reviews, reviews of ineligible topics, and other reviews) were tabulated. In this report, we did not evaluate the primary studies included within the systematic reviews. A list of included and excluded full-text articles is available at the end of the text.

## Data Extraction

We used the current guidelines of reporting of systematic reviews and meta-analyses (PRISMA and MOOSE)5,6 to come up with a list of information items to collect from the published systematic reviews to answer the Key Questions 1, 3, and 4. We did not use a measurement tool to evaluate methodological quality of systematic reviews (for example, AMSTAR16) because our objective was to assess the reporting of validity and generalizability in systematic reviews of implantable medical devices in particular. The operational definitions of each item are described in Table 1.

Currently, there are no specific tools or checklists to evaluate the reporting quality of systematic reviews of implantable medical devices. We consulted the TEP to identify device- and operator-specific information that is relevant and important to the evaluation of these devices. We identified eight device- and operator-specific information items in addition to the 30 systematic review–specific information items identified in the MOOSE and PRISMA guidelines (Table 1 under items reported for Key Question 2).

A standardized form using Google™ docs was used for data extraction.^a^ The basic elements and design of the form were customized to capture all the relevant elements of the Key Questions. We tested the form on several reviews and revised it as necessary before beginning full data extraction of all articles. The data-extraction fields are presented in Appendix B. Each systematic review was extracted by one reviewer, then reviewed and confirmed by at least one other reviewer. Disagreements were resolved through consensus in consultation with a third reviewer. Extracted data were exported to Microsoft Excel®.

a The live form can be viewed and tested here: http://bit.ly/nhK0gl (last accessed on 1/30/2012).

## Data Synthesis

Results and data in the tables were organized on the basis of reporting items for each Key Question. The unit of analysis was the systematic review article. Descriptive analyses were performed and summary statistics calculated regarding the reporting characteristics of systematic reviews. Analyses include whether the reporting followed published guidelines for reporting of systematic reviews and meta-analyses, the reporting of device- or procedure-specific information, the number and types of primary studies analyzed, quality assessment of primary studies, methods for quantitative syntheses, descriptions of heterogeneity (variability in results owing to clinical factors, study design, device-related characteristics) and generalizability, and protocols for reporting of results. Handling of heterogeneity included items that were evaluated within systematic reviews included models for meta-analyses, discussions of statistical heterogeneity, and sensitivity analyses, explicit discussions of clinical heterogeneity, and assessment of heterogeneity and results by subgroups.

We compared key methodological and reporting aspects of reviews pertaining to the five groups of implantable medical devices. These comparisons were performed using the Fisher exact test for categorical variables or the Kruskal-Wallis test for continuous and count variables. Additional a priori subgroup analyses of key methodological and reporting aspects of reviews were conducted comparing systematic reviews of nonrandomized studies to those of randomized trials, comparing reviews that conducted a meta-analysis with those that did not, comparing reviews that reported authors' affiliations to the device industry with those that did not, and comparing reviews published in general medical journals with reviews published in specialty journals. Since some of these variables were recorded on the basis of reporting, it is possible that our classification of variables lacks sensitivity. All quantitative analyses were performed with Excel® and Stata 11® (Stata Corp., College Station, TX). All P-values are two-tailed and considered to indicate significance if less than 0.05; no adjustments for multiple comparisons were performed. In general, a P-value of <0.05 indicates that there are statistically significant differences in reporting items between the groups compared. Additional subgroup analyses were conducted for each of the five groups of implantable medical devices.