# Peer Reviewers

Nancy D. Berkman, Ph.D.

Program on Health Care Quality and Outcomes

Division of Health Services and Social Policy Research

RTI International

Research Triangle Park, NC

Jesse Berlin, Sc.D.

Vice President

Epidemiology

Johnson & Johnson Pharmaceutical

Research and Development

Raritan, NJ

Lisa Hartling, Ph.D.

Assistant Professor

Department of Pediatrics

Faculty of Medicine and Dentistry

Edmonton, Alberta, Canada

James Reston, Ph.D.

Senior Research Analyst

ECRI Institute Evidence-based Practice Center

Health Technology Assessment Group

Plymouth Meeting, PA

Steven Schachter, M.D.

Chief Academic Officer

Center for Integration of Medicine & Innovative Technology

Boston, MA

Tatyana Shamliyan, M.D.

Division of Health Policy and Management

University of Minnesota School of Public Health

Minneapolis, MN

Jonathan Treadwell, Ph.D.

Associate Director

ECRI Institute Evidence-based Practice Center

Health Technology Assessment Group

Plymouth Meeting, PA