# Technical Expert Panel

Naomi Aronson, Ph.D.

Executive Director

Technology Evaluation Center

Blue Cross Blue Shield Association

Chicago, IL

Clifford Goodman, Ph.D.

Senior Vice President

The Lewin Group

Falls Church, VA

Thomas P. Gross, M.D., M.P.H.

Deputy Office Director for Postmarket Science

Office of Surveillance and Biometrics

Center for Devices and Radiological Health

U.S. Food and Drug Administration

Silver Spring, MD

Sarah McClain, M.H.S.

Coverage and Analysis Group

Office of Clinical Standards and Quality

Centers for Medicare & Medicaid Services

Baltimore, MD

Steve E. Phurrough, M.D., M.P.A.

Chief Operating Officer/Senior Clinical Director

Center for Medical Technology Policy

World Trade Center-Baltimore

Baltimore, MD

G. Gregory Raab, Ph.D.

Raab & Associates, Inc.

North Bethesda, MD

Jyme Schafer, M.D., M.P.H.

Director, Division of Medical & Surgical Services

Coverage & Analysis Group

Centers for Medicare & Medicaid Services

Baltimore, MD

Mitchell Sugarman, M.B.A.

Senior Director of Health Economics

Policy and Payment

Santa Rosa, CA