# Background

Over the past decade, advances in the technologies used in medical devices have profoundly transformed clinical practice and patient management.1 According to a recent position paper, studies of medical devices typically do not address in sufficient detail study design features and factors that affect safety and effectiveness, including standardization of outcomes and endpoints, evaluation of device–operator interactions, and evaluation of characteristics of the clinical practice setting.2 The evaluation of medical devices poses a number of methodological challenges, and empirical research evaluating such devices has not been performed. The challenges in conducting assessments of medical devices are secondary to the rapid evolution of technology, practitioner input into design, operator learning curve, and variation in the skill with which they are used.2 These features can potentially impact study outcomes.

Systematic reviews have an established role in medical practice and research. Clinicians use systematic reviews to keep abreast of current research and to provide information on the effectiveness of competing interventions. Agencies including the Centers for Medicare and Medicaid in the United States and the National Institute of Clinical Excellence in the United Kingdom use systematic reviews to prioritize funding or coverage decisions. Health care organizations use systematic reviews to shape policy and inform clinical practice guidelines.3,4 Despite there being many published systematic reviews of medical devices, no empirical evaluation of the reviews has been performed. A thorough empirical appraisal of systematic reviews is needed to critically assess current practices and identify issues and gaps in reporting. The information generated from an empirical appraisal of systematic reviews of medical devices could be used to develop new items in reporting guidelines and improve the conduct and the quality of reporting of systematic reviews of medical devices.

The strength of systematic reviews and meta-analyses relies in part on the clarity of the reporting. Reporting standards may serve to improve the quality of systematic reviews and ultimately to benefit evidence-based patient management and treatment decisions. There have been attempts to improve the general quality of reporting of systematic reviews through guidelines.5,6 Current reviews indicate that adherence to existing systematic review reporting guidelines has generally been low in systematic reviews published in high-impact journals or leading medical journals.7,8 Existing systematic review reporting guidelines include the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) and Meta-analysis of Observational Studies in Epidemiology (MOOSE) guidelines.5,6 While these represent consensus guidelines to improve the quality of reporting in systematic reviews in general, they do not provide guidance for reporting or analyses of variables unique to the field of medical devices. Standardized guidance for researchers conducting systematic reviews on device-related topics could benefit the users of these reviews.

Recently, the Consolidated Standards of Reporting Trials (CONSORT) Statement was modified to extend to trials of nonpharmacological treatments,9,10 but guidelines specific to systematic review of medical devices are still lacking. The rigor of systematic review methods and the clarity with which they are described are as critical as the conduct and validity of the included primary studies. Issues and gaps in reporting of systematic reviews of medical devices can also directly reflect limitations pertaining to primary data. Therefore, a critical appraisal of systematic reviews could also target what must be done to address issues and gaps in primary data.

One large body of devices of interest is implantable medical devices. The Food and Drug Administration (FDA) defines these as devices that are partly or completely inserted into the body or a natural orifice using surgical or medical procedures and are expected to remain in the body or orifice for at least 30 days (or permanently).11 Such devices can be removed only surgically or deactivated medically. Implantable devices also include those that are used to replace an epithelial or eye surface.11 The demand for implantable medical devices in the United States and the cost is projected to increase 8.3 percent annually to $49 billion in 2014, with the fastest-growing categories being spinal implants, cardiac implants, and orthobiologics (substances that accelerate healing of injured bones).12 These increases in device implantation are a result of the aging population, new and expanded indications, easier-to-implant devices, better functioning products, and minimally invasive procedures. For example, an estimated 200,000 hip-replacement surgeries are performed in the U.S. each year in elderly patients.13 The prevalence of functioning cardiac devices, such as permanent pacemakers, is estimated to be over 3 million worldwide.14

As the Evidence-based Practice Center (EPC) designated for the crosscutting concentration of diagnostic testing, imaging technologies, and medical and assistive devices, we conducted a critical appraisal of the quality of reporting in systematic reviews of implantable medical devices. The goals of this project were to evaluate published systematic reviews and meta-analyses to understand the methodologies used; identify current strengths, limitations, deficiencies, and unique challenges; and make recommendations to improve future conduct and reporting. Our findings could be used to inform a broad range of stakeholders, including researchers, clinicians, guideline developers, policymakers, and payers. On the basis of the recommendations of the Technical Expert Panel (TEP), and to ensure inclusion of the most frequently used and expensive devices, we chose to focus on five broad categories of implantable medical devices: cardiac implantable devices, vascular interventional devices, orthopedic implants, skin-replacement grafts, and neurostimulators.

## Key Questions

The following Key Questions were formulated in consultation with the TEP and AHRQ. For each of the proposed Key Questions, with input from the TEP, we operationalized our analysis by creating specific items that could be answered by the systematic reviews (Table 1).

1. How are items such as literature searches, study selection, and results reported in published systematic reviews of implantable medical devices?
2. How do published systematic reviews of implantable medical devices report device- or operator-specific information?
3. How is the reporting of heterogeneity handled in published systematic reviews of implantable medical devices?
4. What are the limitations and issues related to reporting of the quality and generalizability in published systematic reviews of implantable medical devices?

Table 1 Reporting items for systematic reviews of implantable medical devices

Reporting Item | Definition for Adequate Reporting
Items for Key Question 1
Search terms | Keywords for identifying relevant studies for the research questions (i.e., population, interventions, comparator, outcomes, and study design [PICOD]), or complete search strategy (e.g., keywords, medical subject headings) were described or referred to elsewhere.
Searches in multiple databases | Search was conducted in more than one electronic database.
Search years | Time period of the articles searched and included was explicitly described.
Searches in multiple languages | Search was conducted in English and other languages.
Searching for unpublished data | Authors explicitly stated the efforts to include unpublished data (e.g., contact with study authors, searching meeting abstracts or conference preceding, dissertations, etc.[also known as a “grey literature” search]).
Inclusion or exclusion criteria | Definitions of at least two of the PICOD criteria (e.g., randomized controlled trials of drug-eluting stents were included) were reported.
Baseline description of the population | Health status of the population at baseline (i.e., hypertension, diabetes, or coronary artery disease).
Types of interventions/exposures | Interventions or exposures were described (usually includes device name, or a brief description, or type of device).
Types of comparators | Comparators were described (can include another device, or medical treatment, or surgical treatment).
Types of outcomes | Outcomes or endpoints were defined.
Types of study designs | Design of the included studies was described.
Number of included and excluded studies | Number of eligible and ineligible studies identified from the search was reported.
Reasons for exclusion | Reasons for exclusions were described.
Flow diagram for the number of included and excluded studies | A flow diagram showing the progress of study selection was presented.
The total number of primary studies included in the systematic review/meta-analysis | The total number of studies that met inclusion criteria (often reported in the text, tables, or figures).
Graphical presentation of the results | Graphics (e.g., forest plots, trends in outcomes over time, and regression plots) summarizing individual study estimates and overall estimates were presented.
Meta-analyses were performed | Description of whether a meta-analysis was performed.
Costs or cost-effectiveness | Specific discussion of costs of devices or analyses of cost-effectiveness.
Items for Key Question 2
Device or operator-specific
Data on differences across device characteristics were discussed | When multiple devices are used, the differences among devices (e.g., sirolimus-eluting stents, paclitaxel-eluting stents, or bare-metal stents) were discussed across primary studies included.
Data on differences within device characteristics were discussed | Differences within devices (e.g., differences in programming within implantable cardiac defibrillator) were discussed across primary studies included.
Evolution of devices over time were discussed | Discussions within systematic reviews about evolution (change or development) of devices across primary studies evaluated.
Details of training/certification of operator were reported | Details within systematic reviews can include training, prior experience in procedures performed, or any other performance standards.
Ramp-up in provider technique (i.e. learning curve) was discussed | There was a relevant discussion about how the surgeon's experience with the device may affect outcomes.
Level of expertise of team/site were considered | Discussions were made related to the levels of expertise of a team within hospital where operators practice that may impact outcomes.
Practitioner variability were discussed | Variability among operators because different sets of operators are involved in each arm of the trial was discussed.
“Volume at sites” effect were discussed | There was a relevant discussion about how site experience with the device may affect outcomes.
Items for Key Question 3
Handling of heterogeneity
Models for meta-analyses were reported | The methods of combining estimates (e.g., fixed- or random-effects models) were reported.
Meta-analyses used accepted methodology | Accepted methods were used when two or more studies were combined in meta-analysis or five studies or more studies were included in meta-regression analyses. Additionally studies were grouped by design or studies were grouped across similar interventions.
Heterogeneity was assessed or discussed | Sources of heterogeneity within population or among devices were discussed or quantified using statistical methods.
Sensitivity analyses were assessed | Details of the range of treatment estimates and confidence intervals resulting from the various sensitivity analyses were described.
Results by subgroups were considered or quantified | Potentially important subgroup results were discussed (qualitatively) or quantified using accepted methods.
Items for Key Question 4
Assessment of risk of bias | Potential impacts of the biases present in included primary studies were evaluated.
Publication bias was assessed | Quantitative assessment of publication bias (e.g., funnel plot, Begg and Egger tests) was used.
Use of specific checklist for quality items | The list of quality items for the validity (or quality) assessment of studies were applied and reported for each included study.
Study limitations were described | Specific limitations either relating to primary studies or relating to the systematic review methodology were described.
Overall strength of the body of evidence was assessed | Specific methods were used to assess the overall body of evidence (i.e., other than for example “strong evidence”).
Specific future research recommendations were made | Specific suggestions for future research agenda (i.e., other than “more research is needed”) were made.
Funding source was declared | Specific funding source to conduct the systematic review was identified or absence of funding was made explicit.
Sub-item: Authors' affiliation to industry was reported | Whether authors of the systematic review were on the board or employees of a device industry or had received current or previous funding from an industry relevant to the device reviewed was reported.

PICOD = Population, intervention, comparator, outcome, and study design