# A Critical Appraisal of Primary Studies of Implantable Medical Devices

## Background

Despite a significant number of published studies in the field of medical devices, empirical research evaluating medical devices has lagged behind the innovations. As the designated evidenced-based practice center (EPC) for the cross-cutting concentration of diagnostic testing, imaging technologies, and medical and assistive devices, we recently conducted a critical appraisal of reporting of systematic reviews of implantable medical devices. Technical experts identified the following five groups of implantable medical devices as topics of interest for evaluating published systematic reviews: cardiovascular, vascular interventional, orthopedic implants, skin replacement grafts, and neurostimulators.

The technical expert panel opined that the device-specific factors including generation of technology, generalizing results from one device to a similar device, evaluation of device-operator interactions, and evaluation of team are important characteristics in the evaluation of systematic reviews of implantable medical devices. This critical appraisal has evaluated 181 systematic reviews of five selected groups of implantable devices, most of which were published within the last 2 years. Of these reviews, 19 evaluated cardiac implantable devices, 124 evaluated vascular devices, 16 evaluated orthopedic implants, 8 evaluated skin-replacement grafts, and 14 evaluated neurostimulators. We identified that many of the device- or operator-specific information are not reported in the systematic reviews. From reviewing systematic reviews alone, it is unclear whether systematic reviews ignored reporting of device-specific characteristics or if they were not adequately reported in the primary studies.

## Objective

The objective of the project is to conduct a critical appraisal of reporting of published primary studies of implantable medical devices that were incorporated in randomly selected systematic reviews. The specific aims of this work assignment are as follows:

Aim 1 Evaluate the frequency of reporting of device-specific or operator-specific information in a randomly selected subset of primary studies of implantable medical devices.
Aim 2 Assess the association of reporting of device- or operator-specific information in primary studies with study design and outcomes characteristics reported.
Aim 3 Compare reporting of device- or operator-specific characteristics between primary studies and the systematic review that incorporated these studies.

## Methods

### Study Selection and Eligibility Criteria

We sought to evaluate the reporting of device- or operator-specific information in approximately 100 nonoverlapping primary studies of implantable medical devices to compare if reporting in systematic reviews mirror reporting in primary studies. This sample was identified from 181 systematic reviews of implantable medical devices included in an empirical project. We first selected a random subset of 10 systematic reviews, two reviews for each of the five device categories. For each device category, one review had to have reported or discussed at least one of the three device-specific items and the second could not have reported or discussed any. We based the selection of one review with device-specific information and the other without device-specific information because operator-specific information was rarely reported among reviews. For pragmatic reasons we could select only two systematic reviews from each of the five device categories, and a limited number of primary studies incorporated in these reviews. Albeit a small sample, within each of the device categories, we selected one review that reported device-specific information and the other without to get an indication of whether the lack of reporting of device or operator specific information in SRs is related to lack of reporting of these information in primary studies. In order to achieve a feasible number of at least 100 nonoverlapping primary studies, each of the randomly selected systematic reviews had to have a minimum of 9 and a maximum of 20 primary studies. A minimum threshold of less than 9 primary studies in the review would result in fewer than 100 primary studies, while a maximum threshold of more than 20 studies would result in a much larger number of primary studies. Using these thresholds, 62 of the 181 reviews were eligible for review of the primary studies included, of which we selected the random subset of 10 systematic reviews (two per device category).

All primary studies included in the systematic reviews were eligible, irrespective of design or duration of followup. We excluded primary studies reported only in abstract form, because of the limited space provided to report the information we were interested in. We also excluded cost-effective analyses and those not reporting on an implantable device.

### Data Fields and Extraction

For each primary study, the following data was recorded: author and year of publication, description of the population (yes/no for reporting of the disease stage or severity, basic demographics, and inclusion/exclusion criteria), center characteristics (single vs. multi-center), type of study design, source of funding (industry vs. no industry and reporting of author affiliation to industry), device category, concomitant medications, device-specific information (yes/no for reporting of the following items: adequate description of device characteristics, name of model or manufacturer, methods of implantation, and generation of device or modification to the algorithm), operator-specific information (yes/no for reporting of the following items: training/certification of the operator, learning curve, experience of the team, volume at the center, and practitioner variability), primary outcome (yes/no for definition, time points and description of assessment), and type of primary outcome (yes/no for reporting of clinical vs. surrogate). A detailed description of data elements is given in the Additional Information section. Reviewers with expertise in conducting systematic reviews participated in data extraction. All reviewers had to have no conflict of interest and were required to sign a disclosure statement. The selection and data extraction of all eligible papers was carried out by a single reviewer and verified by a second reviewer. Any disagreements were resolved through discussion and consensus among the data extractors or with the help of a third reviewer.

### Data Synthesis and Analyses

All included primary studies were summarized in narrative form and in summary tables that tabulate the important features of each of the three aims. Descriptive analyses were conducted to evaluate reporting characteristics of randomly selected primary studies within each of the five groups of implantable medical devices. All comparisons were performed using the Fisher exact test for categorical variables or the Kruskal-Wallis test for continuous variables.

For Aim1, the reporting of device- or operator-specific information was additionally extracted as binary data (yes/no). We calculated the proportion of studies that reported analyses of device-specific characteristics.

For Aim 2, subgroup analyses were conducted to examine reporting versus no reporting of device- or operator-specific information in the primary studies for the following study-level characteristics: year of publication, population, intervention, comparator, type of study design, and source of funding. All comparisons were performed using the Fisher exact test for categorical variables or the Kruskal-Wallis test for continuous variables.

For Aim 3, we calculated the proportion of primary studies that reported device-specific characteristics and compared these proportions to the quality of reporting of corresponding items in their respective systematic reviews.

## Results

We identified 111 eligible primary studies included in 10 systematic reviews of implantable medical devices (available in Appendix Table F6 in the Additional Information section as well as in the References).

### Aim 1

Evaluate the frequency of reporting of device-specific or operator-specific information in a randomly selected subset of primary studies of implantable medical devices.

At the primary study level, data were considered to be “frequently reported” when they were reported in 50 percent or more of the primary studies. Most of the items relevant to device characteristics were frequently reported in the primary studies (Appendix Table F1). Less consistently reported were evolution of technology or modifications in device during study period (23 percent) and all five operator-/site-specific items including training of providers (4 percent), ramp-up in provider technique or learning curve (5 percent), evaluation of team expertise (10 percent), practitioner variability (24 percent), and volume at each study site (2 percent).

Appendix Table F1 Reporting characteristics in 111 selected primary studies of implantable medical devices

Device-specific Variables | Categories | Number of studies (%)
Name of the model or manufacturer mentioned | Yes | 75 (68)
Name of the model or manufacturer mentioned | No | 36 (33)
Methods of implantation or surgical techniques mentioned | Yes | 82 (74)
Methods of implantation or surgical techniques mentioned | No | 29 (26)
Generation of device, when applicable, or modifications to algorithm described | Yes | 25 (23)
Generation of device, when applicable, or modifications to algorithm described | No | 86 (78)
Description of use of concomitant medications | Yes | 76 (69)
Description of use of concomitant medications | No | 35 (32)
Operator-/site-specific Variables
Details of training/certification of provider | Yes | 4 (4)
Details of training/certification of provider
Details of training/certification of provider | No | 107 (96)
Details of ramp-up in provider technique (i.e., learning curve) | Yes | 5 (5)
Details of ramp-up in provider technique (i.e., learning curve)
Details of ramp-up in provider technique (i.e., learning curve) | No | 106 (96)
Details of level of expertise of team/site | Yes | 11 (10)
Details of level of expertise of team/site
Details of level of expertise of team/site | No | 100 (90)
Practitioner variability were discussed | Yes | 27 (24)
Practitioner variability were discussed
Practitioner variability were discussed | No | 84 (76)
Volume at sites effect were discussed | Yes | 2 (2)
Volume at sites effect were discussed
Volume at sites effect were discussed | No | 109 (98)

### Aim 2

Assess the association of reporting of device- or operator-specific information in primary studies with study design and outcomes characteristics reported.

The description of device-specific information—including name of the model or manufacturer of the device, device implantation techniques, and description of use of concomitant medications—was significantly more frequently reported in studies that reported disease stages (Appendix Table F2). Other variables such as study design and outcome reporting were not associated with reporting of device-specific information (Appendix Tables F3 and F4).

Appendix Table F2 Reporting of device characteristics by whether disease stage or severity was reported

Variables in primary studies | Categories | Number of studies (%) | Disease stage/severity reported N (%) | Disease stage/severity not reported N (%) | P-value for comparison
Name of the model or manufacturer mentioned | Yes | 75 (68) | 69 (92) | 6 (8) | 0.004
Name of the model or manufacturer mentioned | No | 36 (33) | 25 (69) | 11 (31)
Methods of implantation or surgical techniques mentioned | Yes | 82 (74) | 78 (85) | 4 (5) | 0.0
Methods of implantation or surgical techniques mentioned | No | 29 (26) | 16 (55) | 13 (45)
Generation of device, when applicable, or modifications to algorithm described | Yes | 25 (23) | 24 (96) | 1 (4) | 0.11
Generation of device, when applicable, or modifications to algorithm described | No | 86 (78) | 70 (81) | 16 (19)
Description of use of concomitant medications | Yes | 76 (69) | 68 (89) | 8 (11) | 0.05
Description of use of concomitant medications | No | 35 (32) | 26 (74) | 9 (26)

N = number

Appendix Table F3 Reporting of device characteristics by study design

Variables in primary studies | Categories | Number of studies (%) | RCT design N (%) | Nonrandomized or observational N (%) | P-value for comparison
Name of the model or manufacturer mentioned | Yes | 75 (68) | 38 (51) | 37 (49) | 0.16
Name of the model or manufacturer mentioned | No | 36 (33) | 13 (36) | 23 (64)
Methods of implantation or surgical techniques mentioned | Yes | 82 (74) | 42 (51) | 40 (49) | 0.08
Methods of implantation or surgical techniques mentioned | No | 29 (26) | 9 (31) | 20 (69)
Generation of device, when applicable, or modifications to algorithm described | Yes | 25 (23) | 15 (60) | 10 (40) | 0.65
Generation of device, when applicable, or modifications to algorithm described | No | 86 (78) | 45 (52) | 41 (48)
Description of use of concomitant medications | Yes | 76 (69) | 43 (57) | 33 (43) | 0.54
Description of use of concomitant medications | No | 35 (32) | 17 (49) | 18 (51)

N = number, RCT = randomized controlled trial

Appendix Table F4 Reporting of device characteristics by reporting of outcome definition

Variables in primary studies | Categories | Number of studies (%) | Outcome definition reported N (%) | Outcome definition not reported N (%) | P-value for comparison
Name of the model or manufacturer mentioned | Yes | 75 (68) | 38 (51) | 37 (49) | 0.16
Name of the model or manufacturer mentioned | No | 36 (33) | 13 (36) | 23 (64)
Methods of implantation or surgical techniques mentioned | Yes | 82 (74) | 78 (95) | 4 (5) | 0.65
Methods of implantation or surgical techniques mentioned | No | 29 (26) | 27 (93) | 2 (7)
Generation of device, when applicable, or modifications to algorithm described | Yes | 25 (23) | 24 (96) | 1 (4) | 1.0
Generation of device, when applicable, or modifications to algorithm described | No | 86 (78) | 81 (94) | 5 (6)
Description of use of concomitant medications | Yes | 76 (69) | 72 (95) | 4 (5) | 1.0
Description of use of concomitant medications | No | 35 (32) | 33 (94) | 2 (5)

N = number

Because of less consistent reporting of operator-specific information, we did not evaluate this variable with characteristics related to study design and outcomes.

### Aim 3

Compare reporting of device- or operator-specific characteristics between primary studies and the systematic reviews that incorporated these studies.

We compared reporting of device- and operator-specific characteristics between the 10 systematic reviews and the 111 primary studies incorporated in those 10 reviews (Appendix Table F5).

Appendix Table F5 Comparisons of reporting characteristics in selected primary studies of implantable medical devices with reporting in systematic reviews that incorporated these studies

Categories | Cardiac (SR 1) | Cardiac (SR 2) | Vasc (SR 1) | Vasc (SR 2) | Neuro (SR 1) | Neuro (SR 2) | Ortho (SR 1) | Ortho (SR 2) | Skin (SR 1)^*^ | Skin (SR 2)^*^ | Total N Primary studies
N Primary studies per SR | 11 | 11 | 12 | 9 | 15 | 16 | 9 | 6 | 3 | 19 | 111
DEVICE-SPECIFIC
SR reporting device information | Reported | NR | Reported | NR | Reported | NR | Reported | NR | Reported | Reported | Not applicable
Device information in Primary studies N (%) | 0 (0) | 3 (27) | 12 (100) | 6 (67) | 13 (87) | 13 (81) | 8 (89) | 5 (83) | 3 (100) | 18 (95) | 81 (73)
OPERATOR-SPECIFIC
SR reporting operator/team expertise | NR | NR | NR | Reported | NR | NR | NR | NR | NR | NR | Not applicable
Primary studies reporting operator/team expertise N (%) | 0 (0) | 0 (0) | 2 (17) | 4 (44) | 1 (7) | 2 (13) | 0 (0) | 0 (0) | 0 (0) | 3 (16) | 12 (11)
SR reporting details of training | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Not applicable
Primary studies reporting operator training N (%) | 0 (0) | 0 (0) | 1 (8) | 1 (11) | 0 (0) | 0 (0) | 1 (11) | 1 (17) | 0 (0) | 0 (0) | 4 (4)
SR reporting learning curve | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Not applicable
Primary studies reporting learning curve N (%) | 0 (0) | 0 (0) | 1 (8) | 0 (0) | 0 (0) | 0 (0) | 1 (11) | 0 (0) | 1 (33) | 2 (11) | 5 (5)
SR reporting practitioner variability | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Not applicable
Primary studies reporting practitioner variability N (%) | 1 (9) | 9 (1) | 5 (42) | 4 (44) | 1 (7) | 3 (19) | 4 (44) | 5 (83) | 0 (0) | 3 (16) | 27 (24)
SR reporting volume at sites | NR | NR | NR | Reported | NR | NR | NR | NR | NR | NR | Not applicable
Primary studies reporting volume at sites N (%) | 0 (0) | 0 (0) | 1 (8) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 1 (1)

N = number; NR = not reported; SR = systematic reviews

SR 1: Reviews that reported device-specific information, but provided no operator-specific information.

SR 2: Reviews that did not report any device-specific information.

* All skin-replacement reviews reported device-specific information but did not report operator-specific information.

Initially, we had selected 8 device- or operator-specific reporting items of systematic review — three device-specific and five operator-specific — to compare with corresponding items in the 111 primary studies. Comparisons between systematic reviews and primary studies incorporated in these reviews were possible for all five operator-specific characteristics. However, there were limitations in comparing three device-specific items (within-device differences, across-device differences, and evolution of devices) between systematic reviews and primary studies incorporated in these reviews. We found that the three device-specific items were more relevant to systematic reviews as they inherently examined multiple studies published over a period of time that often evaluated multiple devices. For example, a systematic review description of devices can include “Three trials use nitinol stents while the other trials used stainless steel. There is speculation that nitinol stents may perform differently to stainless steel, however this is not apparent in these data.” Such device differences comparisons were not possible in primary studies. Therefore, in primary studies, we assessed whether devices were adequately described using one or more of the following items: name of a device model, methods of implantation, and generation of device. We compared the descriptions of device information in primary studies against the reporting of device-specific information in the corresponding systematic review (Table 5). Descriptions of devices were adequately described in almost three-quarters (81/111) of the primary studies. However, within the cardiac implantable device category, only 14 percent (3/22) of primary studies adequately described devices.

Operator-specific characteristics were rarely discussed across all primary studies with reporting for the five items; reporting varied between approximately one percent (1/111) and 24 percent (27/111). As expected, this observation is generally consistent across the four systematic reviews that lacked reporting on device/operator-specific characteristics. However, despite lack of reporting in the systematic reviews, within the vascular interventional and orthopedic device categories, practitioner variability is discussed in over 50 percent (9/15) of the corresponding primary studies. Nevertheless, level of expertise is considered in almost 45 percent (4/9) of the primary studies for the vascular interventional and the corresponding systematic review also reported the item of level of expertise.

## Conclusion

Most of the items relevant to device characteristics were frequently described in 111 eligible primary studies. Less consistently reported were evolution of technology or modifications in device during study period, as well as all five operator-/site-specific characteristics. Reporting of device- and operator-specific characteristics from 10 systematic reviews were compared to their reporting in the corresponding primary studies. Frequency of reporting at the primary study level was tallied and items were considered to have been frequently reported when they were described in 50 percent or more of the studies. Within all but five of the systematic reviews, the review reported an item when it was frequently reported at the primary study-level. Whenever an item was infrequently reported at the primary level, it was not reported at the review level. The same result was found for averages across all studies: those items that were frequently reported were also reported on the review level in at least one review; infrequently reported items were found in no reviews.

We identified eight device- or operator-specific items that might be of value in reporting in primary studies and systematic reviews of implantable devices that should be incorporated into reporting guidelines.

## Additional Information

[underlined: Data Extraction Form is available at the following link:] https://docs.google.com/spreadsheet/viewform?hl=en_US&formkey=dGFjZG5YZFAyclg4amlhcnExS0JYWUE6MA#gid=0 Population: Description of the following Disease mentioned (Yes/No) Stage or severity (Yes/No) Basic demographics such as age, gender, co-morbid conditions (Yes/No) Inclusion or exclusion criteria reported (Yes/No)
Outcomes: Description of the following Definition of outcomes (at least primary outcome) stated (Yes/No) The time points of outcome measurement described (Yes/No) How the outcomes assessed were described (Yes/No) Clinical outcomes / surrogate outcomes /both
Study design: RCT/n-RCT/Registry/ observational/other Where the population was recruited (single /multi-center)
Funding source identified (Yes/No) If yes, Industry funded (in full or part) (Yes/No) Did one or more authors have industry ties? (Yes/No/Not reported)
Device category: Cardiac implantable / vascular interventional / orthopedic / skin-replacement / neurostimulator Concomitant medications described (Yes/No) Intervention (single device): Description of the following Adequate description of device characteristics? (Yes/No) Level of detail of description of device (High/Low) Name of the model or manufacturer mentioned (Yes/No) Methods of implantation or surgical techniques mentioned (Yes/No) Generation of device, when applicable, or modifications to algorithm described (Yes/No) Intervention (multiple devices): Description of the following for all devices Adequate description of device characteristics? (Yes/No) Level of detail of description of device (High/Low) Name of the model or manufacturer mentioned (Yes/No) Methods of implantation or surgical techniques mentioned (Yes/No) Generation of device, when applicable, or modifications to algorithm described (Yes/No)Separate analyses or data separately presented for multiple devices? (Yes/No)
Is comparator a/an: other device?/medical intervention?/other (describe) Comparator, if it is another device(s): Description of the following Adequate description of device characteristics? (Yes/No) Level of detail of description of device (High/Low) Name of the model or manufacturer mentioned (Yes/No) Methods of implantation or surgical techniques mentioned (Yes/No) Generation of device, when applicable, or modifications to algorithm described (Yes/No)
Comparator is medical or surgical therapy: Description of the following: Medication type and dosage were provided (Yes/No) Surgical therapy technique was described (Yes/No )
Any reporting of device modification during study period (Yes/No)
Details of training/certification of operator were reported (Yes/No)
Learning curve of operator was discussed (Yes/No) Criteria: either the word “learning curve” was used or exclusion of data collected in the early phase of the study to account for issues related to learning curve
Level of expertise of team were considered (Yes/No) Criteria: Any explicit discussions or analyses related to “experienced team or experienced center”
Practitioner variability discussed (Yes/No) Criteria: Any discussion related to use of a device or adjunct technique was at the discretion of the operator.
“Volume at sites” effect was discussed (Yes/No) Criteria: Any discussion related to how the results differ due to volume of patients. This could be results or discussions comparing different centers within a study, if it was multi-center or it could comparing to another study that reported better or worse results

Appendix Table F6 Primary studies description

Variables in primary studies | Categories | N studies (%)
Population
Description of disease for which an implant was used | Yes | 106 (96)
Description of disease for which an implant was used | No | 5 (5)
Description of severity of disease for which an implant was used | Yes | 94 (85)
Description of severity of disease for which an implant was used | No | 17 (15)
Description of demographics or baseline characteristics | Yes | 105 (95)
Description of demographics or baseline characteristics | No | 6 (5)
Description of eligibility criteria | Yes | 102 (92)
Description of eligibility criteria | No | 9 (8)
Number of devices used | Single | 97 (87)
Number of devices used | Multiple | 14 (13)
Outcome
Definition of outcome (at least primary outcome) | Yes | 105 (95)
Definition of outcome (at least primary outcome) | No | 6 (5)
Description of outcome assessment method | Yes | 108 (97)
Description of outcome assessment method | No | 3 (3)
Types of outcomes evaluated | Clinical only | 38 (34)
Types of outcomes evaluated | Surrogate only | 8 (7)
Types of outcomes evaluated | Both | 65 (59)
Other study characteristics
Types of study design | RCT | 51 (46)
Types of study design | Nonrandomized / observational | 60 (54)
Funding source declared | Yes | 59 (53)
Funding source declared | No | 52 (47)
N centers where the study was conducted | Single | 68 (61)
N centers where the study was conducted | Multiple | 39 (35)
N centers where the study was conducted | Unclear | 4 (4)
Types of Comparator
Studies with a medical comparator | Yes | 9 (8)
Studies with a surgical comparator | Yes | 22 (19)
Studies with device comparator | Yes | 31 (28)
Studies without comparator | Yes | 49 (44)
Description of device comparator (n = 31) | | N = 31
Name of the model or manufacturer mentioned | Yes | 24 (77)
| No | 7 (23)
Methods of implantation or surgical techniques mentioned | Yes | 24 (77)
| No | 7 (23)
Generation of device, when applicable, or modifications to algorithm described | Yes | 5 (16)
| No | 25 (84)

## References of Systematic Reviews That Provided Data for Primary Study Evaluation

1 Bartels RH, Donk R, Verbeek AL. No justification for cervical disk prostheses in clinical practice: a meta-analysis of randomized controlled trials. Neurosurgery. 2010;66:1153-1160. [pmid: 20421840].
2 Flora ED, Perera CL, Cameron AL, Maddern GJ. Deep brain stimulation for essential tremor: a systematic review. Mov Disord. 2010;25:1550-1559. [pmid: 20623768].
3 Hoang-Kim A, Scott J, Micera G, Orsini R, Moroni A. Functional assessment in patients with osteoporotic wrist fractures treated with external fixation: a review of randomized trials. Arch Orthop Trauma Surg. 2009;129:105-111. [pmid: 18560856].
4 Korantzopoulos P, Liu T, Li L, Goudevenos JA, Li G. Implantable cardioverter defibrillator therapy in chronic kidney disease: a meta-analysis. Europace. 2009;11:1469-1475. [pmid: 19812050].
5 Lakhan SE, Callaway E. Deep brain stimulation for obsessive-compulsive disorder and treatment-resistant depression: systematic review. BMC Res Notes. 2010;3:60. [pmid: 20202203].
6 Langer A, Rogowski W. Systematic review of economic evaluations of human cell-derived wound care products for the treatment of venous leg and diabetic foot ulcers. BMC Health Serv Res. 2009;9:115. [pmid: 19591680].
7 Naik H, White AJ, Chakravarty T, et al. A meta-analysis of 3,773 patients treated with percutaneous coronary intervention or surgery for unprotected left main coronary artery stenosis. JACC Cardiovasc Interv. 2009;2:739-747. [pmid: 19695542].
8 Pham C, Greenwood J, Cleland H, Woodruff P, Maddern G. Bioengineered skin substitutes for the management of burns: a systematic review. Burns. 2007;33:946-957. [pmid: 17825993].
9 Tagney J. A literature review comparing the experiences and emergent needs of adult patients with permanent pacemakers (PPMs) and implantable cardioverter defibrillators (ICDs). J Clin Nurs. 2010;19:2081-2089. [pmid: 20477907].
10 Twine CP, McLain AD. Graft type for femoro-popliteal bypass surgery. Cochrane Database Syst Rev. 2010:CD001487. [pmid: 20464717].

## References of Included Primary Studies

1 Heller JG, Sasso RC, Papadopoulos SM, et al. Comparison of BRYAN cervical disc arthroplasty with anterior cervical decompression and fusion: clinical and radiographic results of a randomized, controlled, clinical trial. Spine (Phila Pa 1976 ). Jan. 15. 2009;34(2):101-07. [pmid: 19112337].
2 Hreybe H, Razak E, Saba S. Effect of end-stage renal failure and hemodialysis on mortality rates in implantable cardioverter-defibrillator recipients. Pacing Clin Electrophysiol. Sep. 2007;30(9):1091-95. [pmid: 17725751].
3 Jimenez F, Velasco F, Salin-Pascual R, et al. Neuromodulation of the inferior thalamic peduncle for major depression and obsessive compulsive disorder. Acta Neurochir Suppl. 2007;97(Pt 2):393-98. [pmid: 17691327].
4 Jensen LP, Lepantalo M, Fossdal JE, et al. Dacron or PTFE for above-knee femoropopliteal bypass. a multicenter randomised study. Eur J Vasc Endovasc Surg. Jul. 2007;34(1):44-49. [pmid: 17400486].
5 Kamiloski V, Kasapinova K. External fixation in patients with age over 65 years with distal radius fracture. Prilozi. Dec. 2006;27(2):189-99. [pmid: 17211302].
6 Koplan BA, Epstein LM, Albert CM, et al. Survival in octogenarians receiving implantable defibrillators. Am Heart J. Oct. 2006;152(4):714-19. [pmid: 16996846].
7 Jimenez F, Velasco F, Salin-Pascual R, et al. A patient with a resistant major depression disorder treated with deep brain stimulation in the inferior thalamic peduncle. Neurosurgery. Sep. 2005;57(3):585-93. [pmid: 16145540].
8 Krishnan J, Wigg AE, Walker RW, et al. Intra-articular fractures of the distal radius: a prospective randomised controlled trial comparing static bridging and dynamic non-bridging external fixation. J Hand Surg Br. Oct. 2003;28(5):417-21. [pmid: 12954249].
9 Klinkert P, Schepers A, Burger DH, et al. Vein versus polytetrafluoroethylene in above-knee femoropopliteal bypass grafting: five-year results of a randomized controlled trial. J Vasc Surg. Jan. 2003;37(1):149-55. [pmid: 12514593].
10 Hariz GM, Lindberg M, Bergenheim AT. Impact of thalamic deep brain stimulation on disability and health-related quality of life in patients with essential tremor. J Neurol Neurosurg Psychiatry. Jan. 2002;72(1):47-52. [pmid: 11784825].
11 Koller WC, Lyons KE, Wilkinson SB, et al. Long-term safety and efficacy of unilateral deep brain stimulation of the thalamus in essential tremor. Mov Disord. May. 2001;16(3):464-68. [pmid: 11391740].
12 Kohn CS, Petrucci RJ, Baessler C, et al. The effect of psychological intervention on patients' long-term adjustment to the ICD: a prospective study. Pacing Clin Electrophysiol. Apr. 2000;23(4 Pt 1):450-56. [pmid: 10793433].
13 Koller WC, Lyons KE, Wilkinson SB, et al. Efficacy of unilateral deep brain stimulation of the VIM nucleus of the thalamus for essential head tremor. Mov Disord. Sep. 1999;14(5):847-50. [pmid: 10495050].
14 Hutchinson DT, Strenz GO, Cautilli RA. Pins and plaster vs external fixation in the treatment of unstable distal radial fractures. A randomized prospective study. J Hand Surg Br. Jun. 1995;20(3):365-72. [pmid: 7561414].
15 Heimbach D, Luterman A, Burke J, et al. Artificial dermis for major burns. A multi-center randomized clinical trial. Ann Surg. Sep. 1988;208(3):313-20. [pmid: 3048216].
16 Mallet L, Polosan M, Jaafari N, et al. Subthalamic nucleus stimulation in severe obsessive-compulsive disorder. N Engl J Med. Nov. 13. 2008;359(20):2121-34. [pmid: 19005196].
17 Malone DA Jr., Dougherty DD, Rezai AR, et al. Deep brain stimulation of the ventral capsule/ventral striatum for treatment-resistant depression. Biol Psychiatry. Feb. 15. 2009;65(4):267-75. [pmid: 18842257].
18 Lozano AM, Mayberg HS, Giacobbe P, et al. Subcallosal cingulate gyrus deep brain stimulation for treatment-resistant depression. Biol Psychiatry. Sep. 15. 2008;64(6):461-67. [pmid: 18639234].
19 Makikallio TH, Niemela M, Kervinen K, et al. Coronary angioplasty in drug eluting stent era for the treatment of unprotected left main stenosis compared to coronary artery bypass grafting. Ann Med. 2008;40(6):437-43. [pmid: 18608116].
20 Levy R, DellaValle A, Atav AS, et al. The relationship between glomerular filtration rate and survival in patients treated with an implantable cardioverter defibrillator. Clin Cardiol. Jun. 2008;31(6):265-69. [pmid: 18543307].
21 Leosdottir M, Sigurdsson E, Reimarsdottir G, et al. Health-related quality of life of patients with implantable cardioverter defibrillators compared with that of pacemaker recipients. Europace. Mar. 2006;8(3):168-74. [pmid: 16627433].
22 Lee JY, Kondziolka D. Thalamic deep brain stimulation for management of essential tremor. J Neurosurg. Sep. 2005;103(3):400-03. [pmid: 16235669].
23 Mayberg HS, Lozano AM, Voon V, et al. Deep brain stimulation for treatment-resistant depression. Neuron. Mar. 3. 2005;45(5):651-60. [pmid: 15748841].
24 Kumar RJ, Kimble RM, Boots R, et al. Treatment of partial-thickness burns: a prospective, randomized trial using Transcyte. ANZ J Surg. Aug. 2004;74(8):622-26. [pmid: 15315558].
25 Moroni A, Faldini C, Marchetti S, et al. Improvement of the bone-pin interface strength in osteoporotic bone with use of hydroxyapatite-coated tapered external-fixation pins. A prospective, randomized clinical study of wrist fractures. J Bone Joint Surg Am. May. 2001;83-A(5):717-21. [pmid: 11379741].
26 Lal S, Barrow RE, Wolf SE, et al. Biobrane improves wound healing in burned children without increased risk of infection. Shock. Sep. 2000;14(3):314-18. [pmid: 11028549].
27 McQueen MM. Redisplaced unstable fractures of the distal radius. A randomised, prospective study of bridging versus non-bridging external fixation. J Bone Joint Surg Br. Jul. 1998;80(4):665-69. [pmid: 9699834].
28 Lyons KE, Pahwa R, Busenbark KL, et al. Improvements in daily functioning after deep brain stimulation of the thalamus for intractable tremor. Mov Disord. Jul. 1998;13(4):690-92. [pmid: 9686776].
29 McQueen MM, Hajducka C, Court-Brown CM. Redisplaced unstable fractures of the distal radius: a prospective randomised comparison of four methods of treatment. J Bone Joint Surg Br. May. 1996;78(3):404-09. [pmid: 8636175].
30 Madden MR, LaBruna AA, Hajjar DP, et al. Transplantation of cryopreserved cultured epidermal allografts. J Trauma. May. 1996;40(5):743-50. [pmid: 8614073].
31 Murrey D, Janssen M, Delamarter R, et al. Results of the prospective, randomized, controlled multicenter Food and Drug Administration investigational device exemption study of the ProDisc-C total disc replacement versus anterior discectomy and fusion for the treatment of 1-level symptomatic cervical disc disease. Spine J. Apr. 2009;9(4):275-86. [pmid: 18774751].
32 Nuttin BJ, Gabriels LA, Cosyns PR, et al. Long-term electrical capsular stimulation in patients with obsessive-compulsive disorder. Neurosurgery. Jun. 2008;62(6 Suppl 3):966-77. [pmid: 18695582].
33 Nabhan A, Ahlhelm F, Shariat K, et al. The ProDisc-C prosthesis: clinical and radiological experience 1 year after surgery. Spine (Phila Pa 1976 ). Aug. 15. 2007;32(18):1935-41. [pmid: 17700437].
34 Mummaneni PV, Burkus JK, Haid RW, et al. Clinical and radiographic analysis of cervical disc arthroplasty compared with allograft fusion: a randomized controlled clinical trial. J Neurosurg Spine. Mar. 2007;6(3):198-209. [pmid: 17355018].
35 Newall EG, Lever NA, Prasad S, et al. Psychological implications of ICD implantation in a New Zealand population. Europace. Jan. 2007;9(1):20-24. [pmid: 17224417].
36 Palmerini T, Marzocchi A, Marrozzini C, et al. Comparison between coronary angioplasty and coronary artery bypass surgery for the treatment of unprotected left main coronary artery stenosis (the Bologna Registry). Am J Cardiol. Jul. 1. 2006;98(1):54-59. [pmid: 16784920].
37 Pahwa R, Lyons KE, Wilkinson SB, et al. Long-term evaluation of deep brain stimulation of the thalamus. J Neurosurg. Apr. 2006;104(4):506-12. [pmid: 16619653].
38 Nuttin BJ, Gabriels LA, Cosyns PR, et al. Long-term electrical capsular stimulation in patients with obsessive-compulsive disorder. Neurosurgery. Jun. 2003;52(6):1263-72. [pmid: 12762871].
39 Peck MD, Kessler M, Meyer AA, et al. A trial of the effectiveness of artificial dermis in the treatment of patients with burns greater than 45% total body surface area. J Trauma. May. 2002;52(5):971-78. [pmid: 11988667].
40 Obwegeser AA, Uitti RJ, Turk MF, et al. Thalamic stimulation for the treatment of midline tremors in essential tremor patients. Neurology. Jun. 27. 2000;54(12):2342-44. [pmid: 10881269].
41 Nuttin B, Cosyns P, Demeulemeester H, et al. Electrical stimulation in anterior limbs of internal capsules in patients with obsessive-compulsive disorder. Lancet. Oct. 30. 1999;354(9189):1526. [pmid: 10551504].
42 Pahwa R, Lyons KL, Wilkinson SB, et al. Bilateral thalamic stimulation for the treatment of essential tremor. Neurology. Oct. 22. 1999;53(7):1447-50. [pmid: 10534249].
43 Noordenbos J, Dore C, Hansbrough JF. Safety and efficacy of TransCyte for the treatment of partial-thickness burns. J Burn Care Rehabil. Jul. 1999;20(4):275-81. [pmid: 10425589].
44 Naughton G, Mansbridge J, Gentzkow G. A metabolically active human dermal replacement for the treatment of diabetic foot ulcers. Artif Organs. Nov. 1997;21(11):1203-10. [pmid: 9384327].
45 Schefer T, Wolber T, Binggeli C, et al. Long-term predictors of mortality in ICD patients with non-ischaemic cardiac disease: impact of renal function. Europace. Sep. 2008;10(9):1052-59. [pmid: 18687703].
46 Riina J, Patel A, Dietz JW, et al. Comparison of single-level cervical fusion and a metal-on-metal cervical disc replacement device. Am J Orthop (Belle Mead NJ). Apr. 2008;37(4):E71-E77. [pmid: 18535684].
47 Seung KB, Park DW, Kim YH, et al. Stents versus coronary-artery bypass grafting for left main coronary artery disease. N Engl J Med. Apr. 24. 2008;358(17):1781-92. [pmid: 18378517].
48 Scharn DM, Dirven M, Barendregt WB, et al. Human umbilical vein versus heparin-bonded polyester for femoro-popliteal bypass: 5-year results of a prospective randomized multicentre trial. Eur J Vasc Endovasc Surg. Jan. 2008;35(1):61-67. [pmid: 17936036].
49 Smeulders ES, van Haastregt JC, Dijkman-Domanska BK, et al. Nurse- and peer-led self-management programme for patients with an implantable cardioverter defibrillator; a feasibility study. BMC Nurs. 2007;6:6. [pmid: 17880674].
50 Sanmartin M, Baz JA, Claro R, et al. Comparison of drug-eluting stents versus surgery for unprotected left main coronary artery disease. Am J Cardiol. Sep. 15. 2007;100(6):970-73. [pmid: 17826380].
51 Sears SF, Sowell LD, Kuhl EA, et al. The ICD shock and stress management program: a randomized trial of psychosocial treatment to optimize quality of life in ICD patients. Pacing Clin Electrophysiol. Jul. 2007;30(7):858-64. [pmid: 17584267].
52 Robin J, Weinberg K, Tiongson J, et al. Renal dialysis as a risk factor for appropriate therapies and mortality in implantable cardioverter-defibrillator recipients. Heart Rhythm. Oct. 2006;3(10):1196-201. [pmid: 17018351].
53 Parkash R, Stevenson WG, Epstein LM, et al. Predicting early mortality after implantable defibrillator implantation: a clinical risk score for optimal patient selection. Am Heart J. Feb. 2006;151(2):397-403. [pmid: 16442906].
54 Putzke JD, Wharen RE Jr., Obwegeser AA, et al. Thalamic deep brain stimulation for essential tremor: recommendations for long-term outcome analysis. Can J Neurol Sci. Aug. 2004;31(3):333-42. [pmid: 15376477].
55 Post S, Kraus T, Muller-Reinartz U, et al. Dacron vs. polytetrafluoroethylene grafts for femoropopliteal bypass: a prospective randomised multicentre trial. Eur J Vasc Endovasc Surg. Sep. 2001;22(3):226-31. [pmid: 11506515].
56 Sneed NV, Finch NJ, Michel Y. The effect of psychosocial nursing intervention on the mood state of patients with implantable cardioverter defibrillators and their caregivers. Prog Cardiovasc Nurs. 1997;12(2):4-14. [pmid: 9195642].
57 Purdue GF, Hunt JL, Still JM Jr., et al. A multicenter clinical trial of a biosynthetic skin replacement, Dermagraft-TC, compared with cryopreserved human cadaver skin for temporary coverage of excised burn wounds. J Burn Care Rehabil. Jan. 1997;18(1 Pt 1):52-57. [pmid: 9063788].
58 Roumen RM, Hesp WL, Bruggink ED. Unstable Colles' fractures in elderly patients. A randomised trial of external fixation for redisplacement. J Bone Joint Surg Br. Mar. 1991;73(2):307-11. [pmid: 2005162].
59 Spielvogel RL. A histological study of Dermagraft-TC in patients' burn wounds. J Burn Care Rehabil. Jan. 1997;18(1 Pt 2):S16-S18. [pmid: 9063804].
60 Still J, Glat P, Silverstein P, et al. The use of a collagen sponge/living cell composite material to treat donor sites in burn patients. Burns. Dec. 2003;29(8):837-41. [pmid: 14636761].
61 Stonebridge PA, Prescott RJ, Ruckley CV. Randomized trial comparing infrainguinal polytetrafluoroethylene bypass grafting with and without vein interposition cuff at the distal anastomosis. The Joint Vascular Research Group. J Vasc Surg. Oct. 1997;26(4):543-50. [pmid: 9357453].
62 Sturm V, Lenartz D, Koulousakis A, et al. The nucleus accumbens: a target for deep brain stimulation in obsessive-compulsive- and anxiety-disorders. J Chem Neuroanat. Dec. 2003;26(4):293-99. [pmid: 14729131].
63 Sydow O, Thobois S, Alesch F, et al. Multicentre European study of thalamic stimulation in essential tremor: a six year follow up. J Neurol Neurosurg Psychiatry. Oct. 2003;74(10):1387-91. [pmid: 14570831].
64 Tofigh AM, Warnier De WG, Rhissassi B. Comparing vein with collagen impregnated woven polyester prosthesis in above-knee femoropopliteal bypass grafting. Int J Surg. Apr. 2007;5(2):109-13. [pmid: 17448975].
65 Troster AI, Fields JA, Pahwa R, et al. Neuropsychological and quality of life outcome after thalamic stimulation for essential tremor. Neurology. Nov. 10. 1999;53(8):1774-80. [pmid: 10563627].
66 Turakhia MP, Varosy PD, Lee K, et al. Impact of renal function on survival in patients with implantable cardioverter-defibrillators. Pacing Clin Electrophysiol. Mar. 2007;30(3):377-84. [pmid: 17367357].
67 Ushe M, Mink JW, Tabbal SD, et al. Postural tremor suppression is dependent on thalamic stimulation frequency. Mov Disord. Aug. 2006;21(8):1290-92. [pmid: 16685684].
68 Vaillancourt DE, Sturman MM, Verhagen ML, et al. Deep brain stimulation of the VIM thalamic nucleus modifies several features of essential tremor. Neurology. Oct. 14. 2003;61(7):919-25. [pmid: 14557560].
69 van Det RJ, Vriens BH, van der Palen J, et al. Dacron or ePTFE for femoro-popliteal above-knee bypass grafting: short- and long-term results of a multicentre randomised trial. Eur J Vasc Endovasc Surg. Apr. 2009;37(4):457-63. [pmid: 19231253].
70 Veves A, Falanga V, Armstrong DG, et al. Graftskin, a human skin equivalent, is effective in the management of noninfected neuropathic diabetic foot ulcers: a prospective randomized multicenter clinical trial. Diabetes Care. Feb. 2001;24(2):290-95. [pmid: 11213881].
71 Wang X, Chang C, Geng N, et al. Long-term effects of bilateral deep brain stimulation of the subthalamic nucleus on depression in patients with Parkinson's disease. Parkinsonism Relat Disord. Sep. 2009;15(8):587-91. [pmid: 19403325].
72 Wang Y, Cai B, Zhang XS, et al. Clinical outcomes of single level Bryan cervical disc arthroplasty: a prospective controlled study. Zhonghua Wai Ke Za Zhi. Mar. 1. 2008;46(5):328-32. [pmid: 18785525].
73 Wase A, Basit A, Nazir R, et al. Impact of chronic kidney disease upon survival among implantable cardioverter-defibrillator recipients. J Interv Card Electrophysiol. Dec. 2004;11(3):199-204. [pmid: 15548886].
74 White AJ, Kedia G, Mirocha JM, et al. Comparison of coronary artery bypass surgery and percutaneous drug-eluting stent implantation for treatment of left main coronary artery stenosis. JACC Cardiovasc Interv. Jun. 2008;1(3):236-45. [pmid: 19463306].
75 Wu C, Hannan EL, Walford G, et al. Utilization and outcomes of unprotected left main coronary artery stenting and coronary artery bypass graft surgery. Ann Thorac Surg. Oct. 2008;86(4):1153-59. [pmid: 18805151].
76 Werber KD, Raeder F, Brauer RB, et al. External fixation of distal radial fractures: four compared with five pins: a randomized prospective study. J Bone Joint Surg Am. Apr. 2003;85-A(4):660-66. [pmid: 12672842].
77 Waymack P, Duff RG, Sabolinski M. The effect of a tissue engineered bilayered living skin analog, over meshed split-thickness autografts on the healing of excised burn wounds. The Apligraf Burn Study Group. Burns. Nov. 2000;26(7):609-19. [pmid: 10925183].
78 Aalders GJ, van Vroonhoven TJ. Polytetrafluoroethylene versus human umbilical vein in above-knee femoropopliteal bypass: six-year results of a randomized clinical trial. J Vasc Surg. Dec. 1992;16(6):816-23. [pmid: 1460707].
79 Abbott WM, Green RM, Matsumoto T, et al. Prosthetic above-knee femoropopliteal bypass grafting: results of a multicenter randomized prospective trial. Above-Knee Femoropopliteal Study Group. J Vasc Surg. Jan. 1997;25(1):19-28. [pmid: 9013904].
80 Abelson JL, Curtis GC, Sagher O, et al. Deep brain stimulation for refractory obsessive-compulsive disorder. Biol Psychiatry. Mar. 1. 2005;57(5):510-16. [pmid: 15737666].
81 Aouizerate B, Cuny E, Bardinet E, et al. Distinct striatal targets in treating obsessive-compulsive disorder and major depression. J Neurosurg. Oct. 2009;111(4):775-79. [pmid: 19284243].
82 Atroshi I, Brogren E, Larsson GU, et al. Wrist-bridging versus non-bridging external fixation for displaced distal radius fractures: a randomized assessor-blind clinical trial of 38 patients followed for 1 year. Acta Orthop. Jun. 2006;77(3):445-53. [pmid: 16819684].
83 Ballotta E, Renon L, Toffano M, et al. Prospective randomized study on bilateral above-knee femoropopliteal revascularization: Polytetrafluoroethylene graft versus reversed saphenous vein. J Vasc Surg. Nov. 2003;38(5):1051-55. [pmid: 14603216].
84 Barret JP, Dziewulski P, Ramzy PI, et al. Biobrane versus 1% silver sulfadiazine in second-degree pediatric burns. Plast Reconstr Surg. Jan. 2000;105(1):62-65. [pmid: 10626971].
85 Beery TA, Baas LS, Henthorn C. Self-reported adjustment to implanted cardiac devices. J Cardiovasc Nurs. Nov. 2007;22(6):516-24. [pmid: 18090194].
86 Boyce ST, Goretsky MJ, Greenhalgh DG, et al. Comparative assessment of cultured skin substitutes and native skin autograft for treatment of full-thickness burns. Ann Surg. Dec. 1995;222(6):743-52. [pmid: 8526581].
87 Boyce ST, Kagan RJ, Yakuboff KP, et al. Cultured skin substitutes reduce donor skin harvesting for closure of excised, full-thickness burns. Ann Surg. Feb. 2002;235(2):269-79. [pmid: 11807368].
88 Brener SJ, Galla JM, Bryant R III, et al. Comparison of percutaneous versus surgical revascularization of severe unprotected left main coronary stenosis in matched patients. Am J Cardiol. Jan. 15. 2008;101(2):169-72. [pmid: 18178401].
89 Bruch C, Bruch C, Sindermann J, et al. Prevalence and prognostic impact of comorbidities in heart failure patients with implantable cardioverter defibrillator. Europace. Aug. 2007;9(8):681-86. [pmid: 17507354].
90 Bryant JA, De SA, Cabatan C, et al. The impact of thalamic stimulation on activities of daily living for essential tremor. Surg Neurol. Jun. 2003;59(6):479-84. [pmid: 12826348].
91 Buszman PE, Kiesz SR, Bochenek A, et al. Acute and late outcomes of unprotected left main stenting in comparison with surgical revascularization. J Am Coll Cardiol. Feb. 5. 2008;51(5):538-45. [pmid: 18237682].
92 Carpenter MA, Pahwa R, Miyawaki KL, et al. Reduction in voice tremor under thalamic stimulation. Neurology. Mar. 1998;50(3):796-98. [pmid: 9521280].
93 Cassidy C, St Peter SD, Lacey S, et al. Biobrane versus duoderm for the treatment of intermediate thickness burns in children: a prospective, randomized trial. Burns. Nov. 2005;31(7):890-93. [pmid: 16023298].
94 Chen-Scarabelli C, Scarabelli TM. Chronic renal insufficiency is an independent predictor of mortality in implantable cardioverter-defibrillator recipients. Pacing Clin Electrophysiol. Mar. 2007;30(3):371-76. [pmid: 17367356].
95 Chieffo A, Morici N, Maisano F, et al. Percutaneous treatment with drug-eluting stent implantation versus bypass surgery for unprotected left main stenosis: a single-center experience. Circulation. May. 30. 2006;113(21):2542-47. [pmid: 16717151].
96 Cuculich PS, Sanchez JM, Kerzner R, et al. Poor prognosis for patients with chronic kidney disease despite ICD therapy for the primary prevention of sudden death. Pacing Clin Electrophysiol. Feb. 2007;30(2):207-13. [pmid: 17338717].
97 Davids JS, McPherson CA, Earley C, et al. Benefits of cardiac rehabilitation in patients with implantable cardioverter-defibrillators: a patient survey. Arch Phys Med Rehabil. Oct. 2005;86(10):1924-28. [pmid: 16213232].
98 Demling RH, DeSanti L. Management of partial thickness facial burns (comparison of topical antibiotics and bio-engineered skin substitutes). Burns. May. 1999;25(3):256-61. [pmid: 10323611].
99 Devine C, McCollum C. Heparin-bonded Dacron or polytetrafluorethylene for femoropopliteal bypass: five-year results of a prospective randomized multicenter clinical trial. J Vasc Surg. Nov. 2004;40(5):924-31. [pmid: 15557906].
100 Dougherty CM, Thompson EA, Lewis FM. Long-term outcomes of a telephone intervention after an ICD. Pacing Clin Electrophysiol. Nov. 2005;28(11):1157-67. [pmid: 16359281].
101 Duinslaeger LA, Verbeken G, Vanhalle S, et al. Cultured allogeneic keratinocyte sheets accelerate healing compared to Op-site treatment of donor sites in burns. J Burn Care Rehabil. Nov. 1997;18(6):545-51. [pmid: 9404990].
102 Eickhoff JH, Broome A, Ericsson BF, et al. Four years' results of a prospective, randomized clinical trial comparing polytetrafluoroethylene and modified human umbilical vein for below-knee femoropopliteal bypass. J Vasc Surg. Nov. 1987;6(5):506-11. [pmid: 3669200].
103 Falanga V, Margolis D, Alvarez O, et al. Rapid healing of venous ulcers and lack of clinical rejection with an allogeneic cultured human skin equivalent. Human Skin Equivalent Investigators Group. Arch Dermatol. Mar. 1998;134(3):293-300. [pmid: 9521027].
104 Fields JA, Troster AI, Woods SP, et al. Neuropsychological and quality of life outcomes 12 months after unilateral thalamic stimulation for essential tremor. J Neurol Neurosurg Psychiatry. Mar. 2003;74(3):305-11. [pmid: 12588913].
105 Fitchet A, Doherty PJ, Bundy C, et al. Comprehensive cardiac rehabilitation programme for implantable cardioverter-defibrillator patients: a randomised controlled trial. Heart. Feb. 2003;89(2):155-60. [pmid: 12527665].
106 Fratianne R, Papay F, Housini I, et al. Keratinocyte allografts accelerate healing of split-thickness donor sites: applications for improved treatment of burns. J Burn Care Rehabil. Mar. 1993;14(2 Pt 1):148-54. [pmid: 8501101].
107 Gabriels L, Cosyns P, Nuttin B, et al. Deep brain stimulation for treatment-refractory obsessive-compulsive disorder: psychopathological and neuropsychological outcome in three cases. Acta Psychiatr Scand. Apr. 2003;107(4):275-82. [pmid: 12662250].
108 Gerding RL, Emerman CL, Effron D, et al. Outpatient management of partial-thickness burns: Biobrane versus 1% silver sulfadiazine. Ann Emerg Med. Feb. 1990;19(2):121-24. [pmid: 2405749].
109 Greenberg BD, Malone DA, Friehs GM, et al. Three-year outcomes in deep brain stimulation for highly resistant obsessive-compulsive disorder. Neuropsychopharmacology. Nov. 2006;31(11):2384-93. [pmid: 16855529].
110 Hansbrough JF, Mozingo DW, Kealey GP, et al. Clinical trials of a biosynthetic temporary skin replacement, Dermagraft-Transitional Covering, compared with cryopreserved human cadaver skin for temporary coverage of excised burn wounds. J Burn Care Rehabil. Jan. 1997;18(1 Pt 1):43-51. [pmid: 9063787].
111 Vilacosta I, Roman JA. Acute aortic syndrome. Heart. Apr. 2001;85(4):365-68. [pmid: 11250953].