# Tables 1–4 Subgroup Analyses

Appendix Table E1 Reporting of characteristics in systematic reviews of implantable medical devices according to reported author affiliation

Reporting Item | Systematic reviews n (%) Authors affiliation to industry: reported N=38 | Systematic reviews n (%) Author affiliation to industry: not reported N=143 | P-value | Total N=181 n (%)
Search
Search terms were described or referred to elsewhere | 33 (87) | 132 (92) | 0.36 | 165 (91)
Multiple databases were searched | 30 (79) | 114 (79) | 1.0 | 144 (79)
Years searched were described | 33 (87) | 129 (90) | 0.57 | 162 (89)
Multiple languages were included in search | 9 (24) | 53 (37) | 0.18 | 62 (34)
Authors explicitly stated searching for unpublished data | 17 (44) | 63 (44) | 1.0 | 80 (44)
Selection
Inclusion or exclusion criteria were stated | 37 (97) | 138 (96) | 1.00 | 175 (96)
Population at baseline was reported | 38 (100) | 143 (100) | NA | 181 (100)
Interventions/exposures were described | 38 (100) | 143 (100) | NA | 181 (100)
Comparators were described | 38 (100) | 140 (98) | 1.0 | 178 (98)
Outcomes were described | 38 (100) | 143 (100) | NA | 154 (85)
Types of studies included were reported | 37 (97) | 138 (96) | 1.00 | 175 (96)
Number of studies included and excluded were reported | 25 (64) | 91 (63) | 0.49 | 116 (61)
Reasons for exclusion were described | 30 (79) | 109 (76) | 0.83 | 139 (76)
Results
A flow diagram for the number of studies included and excluded was used | 20 (53) | 60 (42) | 0.27 | 80 (44)
The number of primary studies included | 1031 | 3257 | NA | 4288
Results were presented graphically | 29 (76) | 88 (61) | 0.09 | 117 (64)
Meta-analyses were performed | 32 (84) | 92 (64) | 0.02 | 124 (68)
Costs or cost-effectiveness were described | 5 (13) | 37 (26) | 0.13 | 42 (23)
Device-specific Variables
Data on differences across device characteristics were discussed | 16 (42) | 70 (49) | 0.58 | 86 (47)
Data on differences within device characteristics were discussed | 14 (37) | 51 (35) | 0.85 | 65 (36)
Evolution of devices over time were discussed | 6 (16) | 26 (18) | 1.0 | 32 (18)
Operator-specific Variables
Details of training/certification of provider were reported | 2 (5) | 0 (0) | 0.04 | 2 (1)
Ramp-up in provider technique (i.e. learning curve) was discussed | 2 (5) | 11 (8) | 1.0 | 13 (7)
Level of expertise of team/site were considered | 2 (5) | 14 (10) | 0.53 | 16 (9)
Practitioner variability were discussed | 5 (13) | 13 (9) | 0.54 | 18 (10)
“Volume at sites” effect were discussed | 3 (8) | 11 (8) | 1.0 | 14 (8)
Handling of heterogeneity
Models for meta-analyses were reported | 37 (97) | 86 (70) | 0.50 | 123 (99)
Meta-analyses used accepted methodologies (e.g. studies grouped by design) | 27 (71) | 87 (60) | 0.35 | 114 (62)
Heterogeneity was assessed or discussed? | 32 (84) | 107 (74) | 0.28 | 139 (76)
Sensitivity analyses were assessed or discussed | 14 (37) | 51 (35) | 0.85 | 65 (36)
Results by subgroups were considered or quantified | 11 (29) | 29 (20) | 0.27 | 40 (22)
Validity
Risk of bias was assessed | 17 (45) | 62 (43) | 0.85 | 79 (43)
Publication bias was assessed | 13 (34) | 46 (32) | 0.85 | 59 (48)
Quality items or checklists were applied and reported | 14 (37) | 58 (40) | 0.85 | 72 (40)
Discussion
Study limitations were described | 37 (97) | 138 (96) | 1.0 | 175 (96)
Overall strength of the body of evidence was assessed | 5 (13) | 28 (19) | 0.48 | 33 (18)
Specific future research recommendations were made | 30 (79) | 119 (83) | 0.64 | 149 (82)
Funding source was identified | 20 (53) | 56 (39) | 0.14 | 76 (42)

Appendix Table E2 Reporting characteristics in systematic reviews (with or without meta-analyses) of implantable medical devices

Reporting Item | Systematic reviews n (%) Meta-analysis conducted N=124 | Systematic reviews n (%) No meta-analyses conducted N=57 | P-value | Total N=181 n (%)
Search
Search terms were described or referred to elsewhere | 115 (92) | 50 (88) | 0.41 | 165 (91)
Multiple databases were searched | 105 (84) | 39 (68) | 0.02 | 144 (79)
Years searched were described | 113 (91) | 49 (84) | 0.21 | 162 (89)
Multiple languages were included in search | 48 (38) | 14 (25) | 0.09 | 62 (34)
Authors explicitly stated searching for unpublished data | 66 (53) | 14 (25) | <0.001 | 80 (44)
Selection
Inclusion or exclusion criteria were stated | 122 (98) | 53 (91) | 0.03 | 175 (96)
Population at baseline was reported | 124 (100) | 57 (100) | NA | 181 (100)
Interventions/exposures were described | 124 (100) | 57 (100) | NA | 181 (100)
Comparators were described | 123 (99) | 55 (99) | 0.24 | 178 (98)
Outcomes were described | 121 (98) | 57 (100) | 0.55 | 178 (98)
Types of studies included were reported | 121 (98) | 55 (95) | | 176 (96)
Number of studies included and excluded were reported | 91 (73) | 25 (44) | <0.001 | 116 (61)
Reasons for exclusion were described | 105 (85) | 34 (59) | <0.001 | 139 (76)
Results
A flow diagram for the number of studies included and excluded was used | 66 (53) | 14 (25) | <0.001 | 80 (44)
The total number of primary studies included | 2876 | 1412 | NA | 4288
Results were presented graphically | 114 (91) | 3 (5) | <0.001 | 117 (64)
Costs or cost-effectiveness were described | 24 (19) | 18 (32) | 0.09 | 42(23)
Device-specific Variables
Data on differences across device characteristics were discussed | 61 (49) | 25 (44) | 0.63 | 86 (47)
Data on differences within device characteristics were discussed | 48 (38) | 17 (30) | 0.32 | 65 (36)
Evolution of devices over time were discussed | 23 (18) | 15 (26) | 0.24 | 38 (21)
Operator-specific Variables
Details of training/certification of provider were reported | 2 (2) | 0 (0) | 0.47 | 2 (1)
Ramp-up in provider technique (i.e. learning curve) was discussed | 9 (7) | 4 (7) | 0.62 | 13 (7)
Level of expertise of team/site were considered | 10 (8) | 6 (11) | 0.58 | 16 (9)
Practitioner variability were discussed | 13 (11) | 5 (9) | 0.50 | 18 (10)
“Volume at sites” effect were discussed | 7 (6) | 7 (12) | 0.14 | 14 (8)
Handling of heterogeneity
Models for meta-analyses were reported | 121 (97) | NA | NA | 123 (99)^a^
Meta-analyses used accepted methodologies (e.g. studies grouped by design) | 114 (92) | NA | NA | 114 (62)^a^
Heterogeneity was assessed or discussed? | 112 (90) | 27 (48) | <0.001 | 139 (76)
Sensitivity analyses were assessed or discussed | 60 (48) | 5 (9) | <0.001 | 65 (36)
Results by subgroups were considered or quantified | 77 (62) | 15 (26) | <0.001 | 92 (51)
Validity
Risk of bias was assessed | 71 (57) | 8 (14) | <0.001 | 79 (43)
Publication bias was assessed | 59 (46) | NA | NA | 59 (46) a
Quality items or checklists were applied and reported | 53 (43) | 19 (33) | 0.26 | 72 (40)
Discussion
Study limitations were described | 56 (97) | 119 (96) | 1.0 | 175 (96)
Overall strength of the body of evidence was assessed | 14 (11) | 19 (33) | 0.001 | 33 (18)
Specific future research recommendations were made | 96 (77) | 53 (93) | 0.007 | 149 (82)
Funding source was identified | 57 (42) | 19 (33) | 0.15 | 76 (42)
Authors' affiliation to industry was reported | 32 (26) | 6 (10) | 0.03 | 38 (21)

a Among 181 eligible systematic reviews, 124 conducted a meta-analysis. One of 124 studies did not report a model for meta-analysis

Appendix Table E3 Reporting characteristics in systematic reviews of implantable medical devices by study types

Reporting Item | Randomized trials N=66 | Systematic reviews n (%) Nonrandomized/observational studies N=51 | Both N=64 | P-value
Search
Search terms were described or referred to elsewhere | 58 (88) | 48 (94) | 59 (92) | 0.59
Multiple databases were searched | 57 (86) | 32 (63) | 55 (86) | 0.005
Years searched were described | 60 (91) | 44 (86) | 58 (90) | 0.76
Multiple languages were included in search | 31 (47) | 11 (22) | 20 (31) | 0.01
Authors explicitly stated searching for unpublished data | 43 (65) | 15 (29) | 22 (34) | <0.001
Selection
Inclusion or exclusion criteria were stated | 63 (96) | 50 (98) | 62 (97) | 0.79
Population at baseline was reported | 66 (100) | 51 (100) | 64 (100) | NA
Interventions/exposures were described | 66 (100) | 51 (100) | 64 (100) | NA
Comparators were described | 66 (100) | 49 (96) | 64 (99) | 0.20
Outcomes were described | 66 (100) | 51 (100) | 64 (100) | NA
Number of studies included and excluded were reported | 44 (66) | 31 (61) | 41 (61) | 0.53
Reasons for exclusion were described | 48 (73) | 39 (77) | 52 (80) | 0.61
Results
A flow diagram for the number of studies included and excluded was used | 31 (47) | 18 (35) | 31 (48) | 0.36
The number of primary studies included | 962 | 1288 | 2038 | NA
Results were presented graphically | 58 (88) | 21 (41) | 38 (58) | <0.001
Costs or cost-effectiveness were described | 17 (26) | 6 (12) | 19 (29) | 0.06
Meta-analyses were performed | 59 (89) | 23 (45) | 42 (64) | <0.001
Device-specific Variables
Data on differences across device characteristics were discussed | 29 (44) | 23 (45) | 34 (55) | 0.60
Data on differences within device characteristics were discussed | 32 (48) | 11 (22) | 22 (34) | 0.01
Evolution of devices over time were discussed | 12 (18) | 11 (22) | 15 (23) | 0.76
Operator-specific Variables
Details of training/certification of provider were reported | 1 (2) | 0 (0) | 1 (2) | 1.0
Ramp-up in provider technique (i.e. learning curve) was discussed | 3 (5) | 6 (12) | 4 (6) | 0.31
Level of expertise of team/site were considered | 3 (5) | 7 (14) | 6 (9) | 0.20
Practitioner variability were discussed | 6 (9) | 6 (12) | 6 (9) | 0.86
“Volume at sites” effect were discussed | 2 (3) | 6 (12) | 6 (9) | 0.15
Handling of heterogeneity
Models for meta-analyses were reported | 59 (89) | 23 (45) | 42 (64) | <0.001
Meta-analyses used accepted methodologies (e.g. studies grouped by design) | 59 (89) | 20 (39) | 36 (56) | <0.001
Heterogeneity was assessed or discussed? | 42 (63) | 24 (47) | 37 (57) | 0.20
Sensitivity analyses were assessed | 32 (48) | 10 (20) | 23 (35) | 0.005
Results by subgroups were considered or quantified | 19 (29) | 8 (16) | 13 (20) | 0.22
Validity
Risk of bias was assessed | 39 (59) | 15 (29) | 25 (36) | 0.003
Publication bias was assessed | 34 (52) | 8 (16) | 17 (26) | <0.001
Quality items or checklists were applied and reported | 33 (50) | 12 (23) | 27 (42) | 0.01
Discussion
Study limitations were described | 63 (96) | 50 (98) | 62 (97) | 0.79
Overall strength of the body of evidence was assessed | 10 (15) | 10 (19) | 13 (20) | 0.79
Specific future research recommendations were made | 48 (73) | 47 (92) | 54 (84) | 0.03
Funding source was declared | 33 (50) | 22 (43) | 21 (32) | 0.12
Authors' affiliation to industry was reported | 16 (24) | 8 (16) | 14 (22) | 0.55

Appendix Table E4 Reporting of characteristics in systematic reviews of implantable medical devices according to journal type

Reporting Item | Published in general medical journals N=34 | Systematic reviews n (%) Published in specialty medical journals N=147 | P-value | Total N=181 n (%)
Search
Search terms were described or referred to elsewhere | 30 (88) | 135 (92) | 0.51 | 165 (91)
Multiple databases were searched | 30 (88) | 114 (78) | 0.36 | 143 (79)
Years searched were described | 30 (88) | 132 (90) | 0.51 | 162 (90)
Multiple languages were included in search | 15 (44) | 47 (32) | 0.23 | 62 (34)
Authors explicitly stated searching for unpublished data | 24 (71) | 56 (38) | 0.001 | 80 (44)
Selection
Inclusion or exclusion criteria were stated | 34 (100) | 141 (96) | 1.0 | 175 (96)
Population at baseline was reported | 34 (100) | 147 (100) | 1.0 | 181 (100)
Interventions/exposures were described | 34 (100) | 147 (100) | 1.0 | 181 (100)
Comparators were described | 34 (100) | 144 (98.0) | 1.0 | 178 (98)
Outcomes were described | 34 (100) | 144 (98) | 1.0 | 178 (98)
Types of studies included were reported | 34 (100) | 147 (100) | 1.0 | 181 (100)
Number of studies included and excluded were reported | 22 (64.71 | 94 (64.0) | 0.65 | 116 (63)
Reasons for exclusion were described | 27 (79) | 112 (76) | 0.82 | 139 (76.8)
Results
A flow diagram for the number of studies included and excluded was used | 18 (52.9) | 62 (42.2) | 0.34 | 80 (44.2)
The number of primary studies included | 852 | 3436 | NA | 4288
Results were presented graphically | 24 (70.6) | 93 (63.3) | 0.55 | 117 (64.6)
Meta-analyses were performed | 27 (79.4) | 97 (66.0) | 0.15 | 124 (68.5)
Costs or cost-effectiveness were described | 16 (47) | 26 (18) | 0.001 | 42 (23)
Device-specific Variables
Data on differences across device characteristics were discussed | 18 (53) | 68 (46) | 0.57 | 86 (48)
Data on differences within device characteristics were discussed | 11 (32) | 54 (37) | 0.78 | 65 (36)
Evolution of devices over time were discussed | 9 (27) | 29 (20) | 0.48 | 38 (21)
Operator-specific Variables
Details of training/certification of provider were reported | 1 (3) | 1 (1) | 0.34 | 2 (1)
Ramp-up in provider technique (i.e. learning curve) was discussed | 2 (6) | 11 (8) | 1.0 | 13 (7)
Level of expertise of team/site were considered | 1 (3) | 15 (10) | 0.31 | 16 (9)
Practitioner variability were discussed | 1 (3) | 17 (12) | 0.20 | 18 (10)
“Volume at sites” effect were discussed | 2 (6) | 12 (8) | 1.0 | 14 (8)
Handling of heterogeneity
Models for meta-analyses were reported | 27 (79.4) | 97 (66.0) | 0.15 | 123 (69)
Meta-analyses used accepted methodologies (e.g. studies grouped by design) | 27 (79) | 87 (60) | 0.05 | 114 (63)
Heterogeneity was assessed or discussed? | 30 (88) | 109 (74) | 0.002 | 139 (76)
Sensitivity analyses were assessed or discussed | 20 (59) | 45 (31) | 0.003 | 65 (36)
Results by subgroups were considered or quantified | 22 (65) | 70 (48) | 0.08 | 92 (51)
Validity
Risk of bias was assessed | 21 (62) | 58 (40) | 0.02 | 79 (43)
Publication bias was assessed | 17 (50) | 42 (29) | 0.03 | 59 (33)
Quality items or checklists were applied and reported | 21 (62) | 51 (35) | 0.006 | 72 (40)
Discussion
Study limitations were described | 33 (97) | 142 (96) | 1.0 | 175 (96)
Overall strength of the body of evidence was assessed
Specific future research recommendations were made | 26 (76.5) | 122 (83.0) | 0.46 | 148 (81.8)
Funding source was identified | 24 (71) | 52 (35) | 0.0 | 76 (42)
Authors' affiliation to industry was reported. | 8 (24) | 30 (21) | 0.81 | 38 (21)