# Excluded Studies After Full-Text Screening

1 Takagi H, Manabe H, Umemoto T. Drug-eluting versus bare metal stents for saphenous vein graft intervention. Am J Cardiol. 2010;106:1522-1524. (Reject reason: Letter). [pmid: 21059450].
2 Antoniucci D. JETSTENT trial results: impact on ST-segment elevation myocardial infarction interventions. J Invasive Cardiol. 2010;22:23B-25B. (Reject reason: Not a systematic review). [pmid: 20947933].
3 Van Den Broek KC, Habibovic M, Pedersen SS. Emotional distress in partners of patients with an implantable cardioverter defibrillator: a systematic review and recommendations for future research. Pacing Clin Electrophysiol. 2010;33:1442-1450. (Reject reason: Population not of interest). [pmid: 20946298].
4 Campbell JE, Stone PA, Bates MC. Efficacy of embolic protection devices in renal artery stenting. J Cardiovasc Surg (Torino). 2010;51:747-754. (Reject reason: No study search methods or eligibility criteria were reported). [pmid: 20924334].
5 Neschis DG, Scalea TM. Endovascular repair of traumatic aortic injuries. Adv Surg. 2010;44:281-292. (Reject reason: Not a systematic review). [pmid: 20919527].
6 Mazaki T, Masuda H, Takayama T. Prophylactic pancreatic stent placement and post-ERCP pancreatitis: a systematic review and meta-analysis. Endoscopy. 2010;42:842-853. (Reject reason: Topic not of interest). [pmid: 20886403].
7 Amarenco P, Labreuche J, Mazighi M. Lessons from carotid endarterectomy and stenting trials. Lancet. 2010;376:1028-1031. (Reject reason: Editorial). [pmid: 20870079].
8 Naylor AR. Managing patients with symptomatic coronary and carotid artery disease. Perspect Vasc Surg Endovasc Ther. 2010;22:70-76. (Reject reason: Not a systematic review). [pmid: 20858607].
9 Knepper J, Upchurch GR Jr. A review of clinical trials and registries in descending thoracic aortic aneurysms. Semin Vasc Surg. 2010;23:170-175. (Reject reason: Not a systematic review). [pmid: 20826294].
10 Takagi H, Goto SN, Matsui M, Manabe H, Umemoto T. Regarding “preoperative statin therapy is associated with improved outcomes and resource utilization in patients undergoing aortic aneurysm repair”. J Vasc Surg. 2010;52:820-822. (Reject reason: Not a systematic review). [pmid: 20816327].
11 Klein-Weigel P. Spinal cord stimulation - evidence and personal experience. Zentralbl Chir. 2010;135:359-362. (Reject reason: Not a systematic review). [pmid: 20806142].
12 Beattie MJ, Lee MS. Safety and efficacy of drug-eluting stents compared with bare metal stents in ST-elevation myocardial infarction. Rev Cardiovasc Med. 2010;11:57-73. (Reject reason: Not a systematic review). [pmid: 20700088].
13 Navarese EP, Buffon A, De LG, De SS. Effectiveness and safety of drug-eluting stents in vein grafts: a meta-analysis. Am Heart J. 2010;160:e9. (Reject reason: Letter). [pmid: 20691822].
14 Beno M, Rumenapf G. Comparison between hybrid surgical procedure--intraoperative angioplasty and cross-over bypass with aorto-bifemoral bypass in revascularization of iliac arteries. Rozhl Chir. 2009;88:720-724. (Reject reason: Not a systematic review). [pmid: 20662436].
15 Lanjewar C, Jolly S, Mehta SR. Effects of aspiration thrombectomy on mortality in patients with acute myocardial infarction undergoing primary percutaneous coronary intervention: a meta-analysis of the randomized trials. Indian Heart J. 2009;61:335-340. (Reject reason: Intervention not of interest). [pmid: 20635735].
16 Vermeulen H, Westerbos SJ, Ubbink DT. Benefit and harm of iodine in wound care: a systematic review. J Hosp Infect. 2010;76:191-199. (Reject reason: Intervention not of interest). [pmid: 20619933].
17 Sparreboom M, van SJ, van Zanten BG, et al. The effectiveness of bilateral cochlear implants for severe-to-profound deafness in children: a systematic review. Otol Neurotol. 2010;31:1062-1071. (Reject reason: Topic not of interest). [pmid: 20601922].
18 Ellis E III. Discussion. Internal fixation of mandibular angle fractures: a meta-analysis. Plast Reconstr Surg. 2010;125:1761-1762. (Reject reason: Discussion of an included paper). [pmid: 20517102].
19 Cevik C, Nugent K, Perez-Verdia A, Fish RD. Prophylactic implantation of cardioverter defibrillators in idiopathic nonischemic cardiomyopathy for the primary prevention of death: a Not a systematic review. Clin Cardiol. 2010;33:254-260. (Reject reason: Not a systematic review). [pmid: 20513063].
20 Seidl K, Strauss M, Kleemann T. ICD therapy as secondary prevention. Herzschrittmacherther Elektrophysiol. 2010;21:96-101. (Reject reason: Not a systematic review). [pmid: 20505945].
21 Dorr R. Bypass surgery versus percutaneous coronary intervention in patients with diabetes mellitus. Herz. 2010;35:182-190. (Reject reason: No study search methods or eligibility criteria were reported). [pmid: 20467930].
22 Balzer JO, Thalhammer A, Khan V, Zangos S, Vogl TJ, Lehnert T. Angioplasty of the pelvic and femoral arteries in PAOD: results and review of the literature. Eur J Radiol. 2010;75:48-56. (Reject reason: Not a systematic review). [pmid: 20451340].
23 Bellabarba C, Fisher C, Chapman JR, Dettori JR, Norvell DC. Does early fracture fixation of thoracolumbar spine fractures decrease morbidity or mortality?. Spine (Phila Pa 1976). 2010;35:S138-S145. (Reject reason: No implantable device used). [pmid: 20407345].
24 Fiehler J, Bakke SJ, Clifton A, et al. Plea of the defence-critical comments on the interpretation of EVA3S, SPACE and ICSS. Neuroradiology. 2010;52:601-610. (Reject reason: Not a systematic review). [pmid: 20440484].
25 Shi ZS, Loh Y, Walker G, Duckwiler GR. Endovascular thrombectomy for acute ischemic stroke in failed intravenous tissue plasminogen activator versus non-intravenous tissue plasminogen activator patients: revascularization and outcomes stratified by the site of arterial occlusions. Stroke. 2010;41:1185-1192. (Reject reason: No implantable device used). [pmid: 20431084].
26 Carter MJ. Evidence-based medicine: an overview of key concepts. Ostomy Wound Manage. 2010;56:68-85. (Reject reason: Review of concepts). [pmid: 20424294].
27 Bizzarri F, Tudisco A, Ricci M, Rose D, Frati G. Different ways to repair the mitral valve with artificial chordae: a systematic review. J Cardiothorac Surg. 2010;5:22. (Reject reason: No study objectives or eligibility criteria were reported). [pmid: 20377866].
28 Movahed MR. Re.: Provisional vs. complex stenting strategy for coronary bifurcation lesions: meta-analysis of randomized trials. J Invasive Cardiol. 2010;22:148-149. (Reject reason: Letter). [pmid: 20197585].
29 Tamhane UU, Chetcuti S, Hameed I, Grossman PM, Moscucci M, Gurm HS. Safety and efficacy of thrombectomy in patients undergoing primary percutaneous coronary intervention for acute ST elevation MI: a meta-analysis of randomized controlled trials. BMC Cardiovasc Disord. 2010;10:10. (Reject reason: Intervention not of interest). [pmid: 20187958].
30 Pendyala LK, Yin X, Li J, Chen JP, Chronos N, Hou D. The first-generation drug-eluting stents and coronary endothelial dysfunction. JACC Cardiovasc Interv. 2009;2:1169-1177. (Reject reason: Not a systematic review). [pmid: 20129542].
31 Mongeon FP, Belisle P, Joseph L, Eisenberg MJ, Rinfret S. Adjunctive thrombectomy for acute myocardial infarction: A bayesian meta-analysis. Circ Cardiovasc Interv. 2010;3:6-16. (Reject reason: Intervention not of interest). [pmid: 20118149].
32 Marazziti D, Consoli G. Treatment strategies for obsessive-compulsive disorder. Expert Opin Pharmacother. 2010;11:331-343. (Reject reason: Not a systematic review). [pmid: 20102301].
33 Jennings DL, Kalus JS. Addition of cilostazol to aspirin and a thienopyridine for prevention of restenosis after coronary artery stenting: a meta-analysis. J Clin Pharmacol. 2010;50:415-421. (Reject reason: Intervention not of interest). [pmid: 20081227].
34 Ramsey S, Robertson A, Ablett MJ, Meddings RN, Hollins GW, Little B. Evidence-based drainage of infected hydronephrosis secondary to ureteric calculi. J Endourol. 2010;24:185-189. (Reject reason: Topic not of interest). [pmid: 20063999].
35 Knur R. Carotid artery stenting: a systematic review of randomized clinical trials. Vasa. 2009;38:281-291. (Reject reason: Study objectives and search methodology were not reported). [pmid: 19998249].
36 Chen SF, El-Bialy A, Matthews R, Clavijo L. Use of drug-eluting versus bare-metal stents in ST-segment elevation myocardial infarction. J Invasive Cardiol. 2009;21:E206-E212. (Reject reason: Not a systematic review). [pmid: 19901420].
37 Diehm N, Baumgartner I. Routine stent implantation vs. percutaneous transluminal angioplasty in femoropopliteal artery disease: a meta-analysis of randomized controlled trials. Eur Heart J. 2009;30:3083-3084. (Reject reason: Letter). [pmid: 19880846].
38 Matsumura JS, Lee WA, Mitchell RS, et al. The Society for Vascular Surgery Practice Guidelines: management of the left subclavian artery with thoracic endovascular aortic repair. J Vasc Surg. 2009;50:1155-1158. (Reject reason: Guideline document developed from an included paper). [pmid: 19878791].
39 Gorenoi V, Dintsios CM, Schonermark MP, Hagen A. Intravascular brachytherapy for peripheral arterial occlusive disease: systematic review of medical efficacy and health economic modelling. Z Evid Fortbild Qual Gesundhwes. 2009;103:331-340. (Reject reason: Intervention not of interest). [pmid: 19839205].
40 Ehdaie A, Lee MS. Drug-eluting stents in primary percutaneous coronary intervention for ST-elevation myocardial infarction: an up-to-date review of the literature. Minerva Cardioangiol. 2009;57:645-655. (Reject reason: Not a systematic review). [pmid: 19838154].
41 Quenneville SP, Xie X, Brophy JM. The cost-effectiveness of Maze procedures using ablation techniques at the time of mitral valve surgery. Int J Technol Assess Health Care. 2009;25:485-496. (Reject reason: Topic not of interest). [pmid: 19818194].
42 Parrish LC, Miyamoto T, Fong N, Mattson JS, Cerutis DR. Non-bioabsorbable vs. bioabsorbable membrane: assessment of their clinical efficacy in guided tissue regeneration technique. A systematic review. J Oral Sci. 2009;51:383-400. (Reject reason: Topic not of interest). [pmid: 19776505].
43 Tjardes T, Shafizadeh S, Rixen D, et al. Image-guided spine surgery: state of the art and future directions. Eur Spine J. 2010;19:25-45. (Reject reason: Intervention not of interest). [pmid: 19763640].
44 Eeckhout E. Thrombectomy in acute ST-elevation myocardial infarction: keep it simple. Eur Heart J. 2009;30:2180-2181. (Reject reason: Intervention not of interest). [pmid: 19726438].
45 Burzotta F, De VM, Gu YL, et al. Clinical impact of thrombectomy in acute ST-elevation myocardial infarction: an individual patient-data pooled analysis of 11 trials. Eur Heart J. 2009;30:2193-2203. (Reject reason: Intervention not of interest). [pmid: 19726437].
46 Kingston GT, Darby CR, Roberts IS. The pathology of depopulated bovine ureter xenografts utilized for vascular access in haemodialysis patients. Histopathology. 2009;55:154-160. (Reject reason: Topic not of interest). [pmid: 19694822].
47 Byrne RA, Sarafoff N, Kastrati A, Schomig A. Drug-eluting stents in percutaneous coronary intervention: a benefit-risk assessment. Drug Saf. 2009;32:749-770. (Reject reason: Not a systematic review). [pmid: 19670915].
48 Pedersen SS, van den BM, Theuns DA. A viewpoint on the impact of device advisories on patient-centered outcomes. Pacing Clin Electrophysiol. 2009;32:1006-1011. (Reject reason: Not a systematic review). [pmid: 19659620].
49 Noordeen MH, Garrido E, Tucker SK, Elsebaie HB. The surgical treatment of congenital kyphosis. Spine (Phila Pa 1976). 2009;34:1808-1814. (Reject reason: Not a systematic review). [pmid: 19644332].
50 Hedequist DJ. Instrumentation and fusion for congenital spine deformities. Spine (Phila Pa 1976). 2009;34:1783-1790. (Reject reason: Not a systematic review). [pmid: 19644329].
51 Garg S, Serruys P. Drug-eluting stents are safe. Clin Pharmacol Ther. 2009;86:130-132. (Reject reason: Not a systematic review). [pmid: 19621006].
52 Nicolaou G. Endovascular treatment of blunt traumatic thoracic aortic injury. Semin Cardiothorac Vasc Anesth. 2009;13:106-112. (Reject reason: Not a systematic review). [pmid: 19617250].
53 Drug-eluting coronary stents: many meta-analyses, little benefit. Prescrire Int. 2009;18:70-74. (Reject reason: Not a systematic review). [pmid: 19585727].
54 Chung KC, Ghori AK. Discussion. Systematic review of skin graft donor-site dressings. Plast Reconstr Surg. 2009;124:307-308. (Reject reason: A review of systematic reviews). [pmid: 19568093].
55 Sears SF, Matchett M, Conti JB. Effective management of ICD patient psychosocial issues and patient critical events. J Cardiovasc Electrophysiol. 2009;20:1297-1304. (Reject reason: Not a systematic review). [pmid: 19563356].
56 Ojike NI, Roberts CS, Giannoudis PV. Compartment syndrome of the thigh: a systematic review. Injury. 2010;41:133-136. (Reject reason: Topic not of interest). [pmid: 19555950].
57 Karpov I, Samko AN, Buza VV. Drug-eluting stents: long-term safety. Ter Arkh. 2009;81:36-41. (Reject reason: Not a systematic review). [pmid: 19537584].
58 Ilahi OA, Nolla JM, Ho DM. Intra-tunnel fixation versus extra-tunnel fixation of hamstring anterior cruciate ligament reconstruction: a meta-analysis. J Knee Surg. 2009;22:120-129. (Reject reason: No implantable devices, comparison of autografts). [pmid: 19476176].
59 Geissler HJ, Schlensak C, Sudkamp M, Beyersdorf F. Heart valve surgery today: indications, operative technique, and selected aspects of postoperative care in acquired valvular heart disease. Dtsch Arztebl Int. 2009;106:224-233. (Reject reason: Not a systematic review). [pmid: 19471589].
60 De VM, Burzotta F, Biondi-Zoccai GG, et al. Individual patient-data meta-analysis comparing clinical outcome in patients with ST-elevation myocardial infarction treated with percutaneous coronary intervention with or without prior thrombectomy. ATTEMPT study: a pooled Analysis of Trials on ThrombEctomy in acute Myocardial infarction based on individual PatienT data. Vasc Health Risk Manag. 2009;5:243-247. (Reject reason: Intervention not of interest). [pmid: 19436647].
61 Ertas G, van Beusekom HM, van der Giessen WJ. Late stent thrombosis, endothelialisation and drug-eluting stents. Neth Heart J. 2009;17:177-180. (Reject reason: Not a systematic review). [pmid: 19421365].
62 Digby GC, Daubney ME, Baggs J, et al. Physiotherapy and cardiac rhythm devices: a review of the current scope of practice. Europace. 2009;11:850-859. (Reject reason: Not a systematic review). [pmid: 19411677].
63 Ng VG, Stone GW. Diabetics and drug-eluting stents in ST segment elevation myocardial infarction: confidence in numbers. Rev Esp Cardiol. 2009;62:343-346. (Reject reason: Editorial). [pmid: 19401117].
64 Yokochi F. Deep brain stimulation for Parkinson's disease and dystonia. Brain Nerve. 2009;61:473-483. (Reject reason: Not a systematic review). [pmid: 19378817].
65 Sakhuja R, Keebler M, Lai TS, McLaughlin GC, Thakur R, Bhatt DL. Meta-analysis of mortality in dialysis patients with an implantable cardioverter defibrillator. Am J Cardiol. 2009;103:735-741. (Reject reason: Duplicate retrieval). [pmid: 19231344].
66 Oswald H, Klein G, Struber M, Gardiwal A. Implantable defibrillator with left ventricular assist device compatibility. Interact Cardiovasc Thorac Surg. 2009;8:579-580. (Reject reason: Primary study). [pmid: 19223309].
67 Mandava P, Kent TA. Percutaneous clot removal in acute ischemic stroke. Arch Neurol. 2009;66:283-284. (Reject reason: Commentary). [pmid: 19204174].
68 Naylor AR. Does the risk of post-CABG stroke merit staged or synchronous reconstruction in patients with symptomatic or asymptomatic carotid disease?. J Cardiovasc Surg (Torino). 2009;50:71-81. (Reject reason: Not a systematic review). [pmid: 19179993].
69 Amin AP, Mamtani MR, Kulkarni H. Factors influencing the benefit of adjunctive devices during percutaneous coronary intervention in ST-segment elevation myocardial infarction: meta-analysis and meta-regression. J Interv Cardiol. 2009;22:49-60. (Reject reason: Intervention not of interest). [pmid: 19141090].
70 Takkenberg JJ, Klieverik LM, Schoof PH, et al. The Ross procedure: a systematic review and meta-analysis. Circulation. 2009;119:222-228. (Reject reason: Evaluation of autograft). [pmid: 19118260].
71 Jolly SS, Amlani S, Hamon M, Yusuf S, Mehta SR. Radial versus femoral access for coronary angiography or intervention and the impact on major bleeding and ischemic events: a systematic review and meta-analysis of randomized trials. Am Heart J. 2009;157:132-140. (Reject reason: Topic not of interest). [pmid: 19081409].
72 Sleilaty G, Achouh P, Fabiani JN. Stenting or coronary artery bypass surgery for triple vessel disease?. Ann Cardiol Angeiol (Paris). 2009;58:104-112. (Reject reason: Not a systematic review). [pmid: 18930176].
73 Patel TR, Bulsara KR. Current strategies for the treatment of intracranial atherosclerotic internal carotid artery stenosis. Neurosurg Rev. 2009;32:23-27. (Reject reason: Narrative review). [pmid: 18818960].
74 Hanson MD, Gauld M, Wathen CN, Macmillan HL. Nonpharmacological interventions for acute wound care distress in pediatric patients with burn injury: a systematic review. J Burn Care Res. 2008;29:730-741. (Reject reason: Intervention not of interest). [pmid: 18695617].
75 De LG, Cassetti E, Marino P. Impact of duration of clopidogrel prescription on outcome of DES as compared to BMS in primary angioplasty: a meta-regression analysis of randomized trials. J Thromb Thrombolysis. 2009;27:365-378. (Reject reason: Intervention not of interest). [pmid: 18498003].
76 Tomaske M, Bauersfeld U. Experience with implantable cardioverter-defibrillator therapy in grown-ups with congenital heart disease. Pacing Clin Electrophysiol. 2008;31(Suppl 1):S35-S37. (Reject reason: Narrative review). [pmid: 18226033].
77 Celik T, Iyisoy A, Yuksel UC, Isik E. Optimal revascularization strategy for diabetic patients with multivessel coronary artery disease: the duel between old hero and young warrior. Int J Cardiol. 2009;131:269-270. (Reject reason: Editorial). [pmid: 17692947].
78 Bryant J, Brodin H, Loveman E, Payne E, Clegg A. The clinical and cost-effectiveness of implantable cardioverter defibrillators: a systematic review. Health Technol Assess. 2005;9:1-150. iii. (Reject reason: Duplication publication). [pmid: 16153353].
79 Pourati I, Hyder M, Rosenthal L. Indications for implantable cardiac defibrillators in patients with congestive heart failure: implications of the sudden cardiac death in heart failure trial. Curr Cardiol Rep. 2005;7:223-228. (Reject reason: Narrative review). [pmid: 15865865].
80 Nanthakumar K, Epstein AE, Kay GN, Plumb VJ, Lee DS. Prophylactic implantable cardioverter-defibrillator therapy in patients with left ventricular systolic dysfunction: a pooled analysis of 10 primary prevention trials. J Am Coll Cardiol. 2004;44:2166-2172. (Reject reason: Met sufficient number of reviews). [pmid: 15582314].
81 Seidl K, Strauss M, Kleemann T. ICD therapy as secondary prevention. Herzschrittmacherther Elektrophysiol. 2010;21:96-101. (Reject reason: Narrative review). [pmid: 20505945].