# List of Included Studies in the Analyses

## Cardiac Implants

1 Berry SM, Ishak KJ, Luce BR, Berry DA. Bayesian meta-analyses for comparative effectiveness and informing coverage decisions. Med Care. 2010;48:S137-S144. [pmid: 20473185].
2 Brilakis ES, Friedman PA, Maounis TN, et al. Programmed ventricular stimulation in patients with idiopathic dilated cardiomyopathy and syncope receiving implantable cardioverter-defibrillators: a case series and a systematic review of the literature. Int J Cardiol. 2005;98:395-401. [pmid: 15708170].
3 Buxton M, Caine N, Chase D, et al. A review of the evidence on the effects and costs of implantable cardioverter defibrillator therapy in different patient groups, and modelling of cost-effectiveness and cost-utility for these groups in a UK context. Health Technol Assess. 2006;10:iii-xi. 1. [pmid: 16904046].
4 Cheng JM, den Uil CA, Hoeks SE, et al. Percutaneous left ventricular assist devices vs. intra-aortic balloon pump counterpulsation for treatment of cardiogenic shock: a meta-analysis of controlled trials. Eur Heart J. 2009;30:2102-2108. [pmid: 19617601].
5 Desai AS, Fang JC, Maisel WH, Baughman KL. Implantable defibrillators for the prevention of mortality in patients with nonischemic cardiomyopathy: a meta-analysis of randomized controlled trials. JAMA. 2004;292:2874-2879. [pmid: 15598919].
6 Ezekowitz JA, Rowe BH, Dryden DM, et al. Systematic review: implantable cardioverter defibrillators for adults with left ventricular systolic dysfunction. Ann Intern Med. 2007;147:251-262. [pmid: 17709759].
7 Ghanbari H, Dalloul G, Hasan R, et al. Effectiveness of implantable cardioverter-defibrillators for the primary prevention of sudden cardiac death in women with advanced heart failure: a meta-analysis of randomized controlled trials. Arch Intern Med. 2009;169:1500-1506. [pmid: 19752408].
8 Henyan NN, White CM, Gillespie EL, Smith K, Coleman CI, Kluger J. The impact of gender on survival amongst patients with implantable cardioverter defibrillators for primary prevention against sudden cardiac death. J Intern Med. 2006;260:467-473. [pmid: 17040253].
9 Huang Y, Wu W, Cao Y, Qu N. All cause mortality of cardiac resynchronization therapy with implantable cardioverter defibrillator: a meta-analysis of randomized controlled trials. Int J Cardiol. 2010;145:413-417. [pmid: 20541819].
10 Korantzopoulos P, Liu T, Li L, Goudevenos JA, Li G. Implantable cardioverter defibrillator therapy in chronic kidney disease: a meta-analysis. Europace. 2009;11:1469-1475. [pmid: 19812050].
11 Lam SK, Owen A. Combined resynchronisation and implantable defibrillator therapy in left ventricular dysfunction: Bayesian network meta-analysis of randomised controlled trials. BMJ. 2007;335:925. [pmid: 17932160].
12 Pedersen SS, Sears SF, Burg MM, Van Den Broek KC. Does ICD indication affect quality of life and levels of distress?. Pacing Clin Electrophysiol. 2009;32:153-156. [pmid: 19170902].
13 Sakhuja R, Keebler M, Lai TS, McLaughlin GC, Thakur R, Bhatt DL. Meta-analysis of mortality in dialysis patients with an implantable cardioverter defibrillator. Am J Cardiol. 2009;103:735-741. [pmid: 19231344].
14 Salukhe TV, Briceno NI, Ferenczi EA, Sutton R, Francis DP. Is there benefit in implanting defibrillators in patients with severe heart failure?. Heart. 2010;96:599-603. [pmid: 20357388].
15 Santangeli P, Di BL, Dello RA, et al. Meta-analysis: age and effectiveness of prophylactic implantable cardioverter-defibrillators. Ann Intern Med. 2010;153:592-599. [pmid: 21041579].
16 Santangeli P, Pelargonio G, Dello RA, et al. Gender differences in clinical outcome and primary prevention defibrillator benefit in patients with severe left ventricular dysfunction: a systematic review and meta-analysis. Heart Rhythm. 2010;7:876-882. [pmid: 20380893].
17 Tagney J. A literature review comparing the experiences and emergent needs of adult patients with permanent pacemakers (PPMs) and implantable cardioverter defibrillators (ICDs). J Clin Nurs. 2010;19:2081-2089. [pmid: 20477907].
18 Theuns DA, Smith T, Hunink MG, Bardy GH, Jordaens L. Effectiveness of prophylactic implantation of cardioverter-defibrillators without cardiac resynchronization therapy in patients with ischaemic or non-ischaemic heart disease: a systematic review and meta-analysis. Europace. 2010;12:1564-1570. [pmid: 20974768].
19 Wells G, Parkash R, Healey JS, et al. Cardiac resynchronization therapy: a meta-analysis of randomized controlled trials. CMAJ. 2011;183:421-429. [pmid: 21282316].

## Vascular Interventions

1 Abdel-Latif A, Mukherjee D, Mesgarzadeh P, Ziada KM. Drug-eluting stents in patients with end-stage renal disease: meta-analysis and systematic review of the literature. Catheter Cardiovasc Interv. 2010;76:942-948. [pmid: 20506492].
2 Abela R, Ivanova S, Lidder S, Morris R, Hamilton G. An analysis comparing open surgical and endovascular treatment of atherosclerotic renal artery stenosis. Eur J Vasc Endovasc Surg. 2009;38:666-675. [pmid: 19726208].
3 Akowuah E, Angelini G, Bryan AJ. Open versus endovascular repair of traumatic aortic rupture: a systematic review. J Thorac Cardiovasc Surg. 2009;138:768-769. [pmid: 19698868].
4 Alghamdi AA, Elmistekawy EM, Singh SK, Latter DA. Is concomitant surgery for moderate functional mitral regurgitation indicated during aortic valve replacement for aortic stenosis? A systematic review and evidence-based recommendations. J Card Surg. 2010;25:182-187. [pmid: 20021509].
5 Amin AP, Mamtani MR, Kulkarni H. Factors influencing the benefit of adjunctive devices during percutaneous coronary intervention in ST-segment elevation myocardial infarction: meta-analysis and meta-regression. J Interv Cardiol. 2009;22:49-60. [pmid: 19141090].
6 Antoniou GA, Koutsias S, Karathanos C, Sfyroeras GS, Vretzakis G, Giannoukas AD. Endovascular stent-graft repair of major abdominal arteriovenous fistula: a systematic review. J Endovasc Ther. 2009;16:514-523. [pmid: 19702345].
7 Antoniou GA, Lazarides MK, Georgiadis GS, Sfyroeras GS, Nikolopoulos ES, Giannoukas AD. Lower-extremity arteriovenous access for haemodialysis: a systematic review. Eur J Vasc Endovasc Surg. 2009;38:365-372. [pmid: 19596598].
8 Antoniou GA, Koutsias S, Antoniou SA, Georgiakakis A, Lazarides MK, Giannoukas AD. Outcome after endovascular stent graft repair of aortoenteric fistula: A systematic review. J Vasc Surg. 2009;49:782-789. [pmid: 19028054].
9 Antoniou GA, El SK, Hamady M, Wolfe JH. Hybrid treatment of complex aortic arch disease with supra-aortic debranching and endovascular stent graft repair. Eur J Vasc Endovasc Surg. 2010;39:683-690. [pmid: 20227895].
10 Athappan G, Ponniah T. Clinical outcomes of dialysis patients after implantation of DES: meta analysis and systematic review of literature. Minerva Cardioangiol. 2009;57:291-297. [pmid: 19513010].
11 Athappan G, Ponniah T, Jeyaseelan L. True coronary bifurcation lesions: meta-analysis and review of literature. J Cardiovasc Med (Hagerstown). 2010;11:103-110. [pmid: 19952947].
12 Bachoo P, Thorpe PA, Maxwell H, Welch K. Endovascular stents for intermittent claudication. Cochrane Database Syst Rev. 2010:CD003228. [pmid: 20091540].
13 Bakoyiannis C, Kalles V, Economopoulos K, Georgopoulos S, Tsigris C, Papalambros E. Hybrid procedures in the treatment of thoracoabdominal aortic aneurysms: a systematic review. J Endovasc Ther. 2009;16:443-450. [pmid: 19702357].
14 Bakoyiannis C, Economopoulos KP, Georgopoulos S, Bastounis E, Papalambros E. Carotid endarterectomy versus carotid angioplasty with or without stenting for treatment of carotid artery stenosis: an updated meta-analysis of randomized controlled trials. Int Angiol. 2010;29:205-215. [pmid: 20502407].
15 Bakoyiannis CN, Economopoulos KP, Georgopoulos S, et al. Fenestrated and branched endografts for the treatment of thoracoabdominal aortic aneurysms: a systematic review. J Endovasc Ther. 2010;17:201-209. [pmid: 20426638].
16 Benedetto U, Melina G, Angeloni E, et al. Coronary artery bypass grafting versus drug-eluting stents in multivessel coronary disease. A meta-analysis on 24,268 patients. Eur J Cardiothorac Surg. 2009;36:611-615. [pmid: 19394857].
17 Benedetto U, Melina G, Roscitano A, et al. Does combined mitral valve surgery improve survival when compared to revascularization alone in patients with ischemic mitral regurgitation? A meta-analysis on 2479 patients. J Cardiovasc Med (Hagerstown). 2009;10:109-114. [pmid: 19377377].
18 Beohar N, Meyers SN, Erdogan A, et al. Off-label use of drug-eluting versus bare metal stents: a lesion-specific systematic review of long-term outcomes. J Interv Cardiol. 2010;23:528-545. [pmid: 20735712].
19 Biondi-Zoccai GG, Sangiorgi G, Lotrionte M, et al. Infragenicular stent implantation for below-the-knee atherosclerotic disease: clinical evidence from an international collaborative meta-analysis on 640 patients. J Endovasc Ther. 2009;16:251-260. [pmid: 19642789].
20 Blackhouse G, Hopkins R, Bowen JM, et al. A cost-effectiveness model comparing endovascular repair to open surgical repair of abdominal aortic aneurysms in Canada. Value Health. 2009;12:245-252. [pmid: 18783394].
21 Bonati LH, Dobson J, Algra A, et al. Short-term outcome after stenting versus endarterectomy for symptomatic carotid stenosis: a preplanned meta-analysis of individual patient data. Lancet. 2010;376:1062-1073. [pmid: 20832852].
22 Bouma W, Klinkenberg TJ, van dH, I, et al. Mitral valve surgery for mitral regurgitation caused by Libman-Sacks endocarditis: a report of four cases and a systematic review of the literature. J Cardiothorac Surg. 2010;5:13. [pmid: 20331896].
23 Brar SS, Gray WA, Dangas G, et al. Bifurcation stenting with drug-eluting stents: a systematic review and meta-analysis of randomised trials. EuroIntervention. 2009;5:475-484. [pmid: 19755337].
24 Brar SS, Leon MB, Stone GW, et al. Use of drug-eluting stents in acute myocardial infarction: a systematic review and meta-analysis. J Am Coll Cardiol. 2009;53:1677-1689. [pmid: 19406344].
25 Brener SJ, Prasad AJ, Khan Z, Sacchi TJ. The relationship between late lumen loss and restenosis among various drug-eluting stents: a systematic review and meta-regression analysis of randomized clinical trials. Atherosclerosis. 2011;214:158-162. [pmid: 21122853].
26 Brilakis ES, Saeed B, Banerjee S. Drug-eluting stents in saphenous vein graft interventions: a systematic review. EuroIntervention. 2010;5:722-730. [pmid: 20142225].
27 Brown RA, Williams M, Barker CM, et al. Sex-specific outcomes following revascularization with zotarolimus-eluting stents: comparison of angiographic and late-term clinical results. Catheter Cardiovasc Interv. 2010;76:804-813. [pmid: 20815043].
28 Bryant J, Brodin H, Loveman E, Clegg A. Clinical effectiveness and cost-effectiveness of implantable cardioverter defibrillators for arrhythmias: a systematic review and economic evaluation. Int J Technol Assess Health Care. 2007;23:63-70. [pmid: 17234018].
29 Chakravarty T, White AJ, Buch M, et al. Meta-analysis of incidence, clinical characteristics and implications of stent fracture. Am J Cardiol. 2010;106:1075-1080. [pmid: 20920641].
30 Chambers D, Epstein D, Walker S, et al. Endovascular stents for abdominal aortic aneurysms: a systematic review and economic model. Health Technol Assess. 2009;13:1-318. iii. [pmid: 19849958].
31 Chambers D, Fayter D, Paton F, Woolacott N. Use of non-randomised evidence alongside randomised trials in a systematic review of endovascular aneurysm repair: strengths and limitations. Eur J Vasc Endovasc Surg. 2010;39:26-34. [pmid: 19836274].
32 Cheung EW, Wong WH, Cheung YF. Meta-analysis of pulmonary valve replacement after operative repair of tetralogy of fallot. Am J Cardiol. 2010;106:552-557. [pmid: 20691315].
33 Claessen BE, Stone GW, Smits PC, et al. Would SYNTAX have been a positive trial if XIENCE V had been used instead of TAXUS?: A meta-analysis of a first-generation vs. a second-generation drug-eluting stent system. Neth Heart J. 2010;18:451-453. [pmid: 20862241].
34 Colmenarez HJ, Escaned J, Fernandez C, et al. Efficacy and safety of drug-eluting stents in chronic total coronary occlusion recanalization: a systematic review and meta-analysis. J Am Coll Cardiol. 2010;55:1854-1866. [pmid: 20413038].
35 De LG, Valgimigli M, Spaulding C, et al. Short and long-term benefits of sirolimus-eluting stent in ST-segment elevation myocardial infarction: a meta-analysis of randomized trials. J Thromb Thrombolysis. 2009;28:200-210. [pmid: 19190859].
36 De LG, Stone GW, Suryapranata H, et al. Efficacy and safety of drug-eluting stents in ST-segment elevation myocardial infarction: a meta-analysis of randomized trials. Int J Cardiol. 2009;133:213-222. [pmid: 18394731].
37 Dibra A, Tiroch K, Schulz S, et al. Drug-eluting stents in acute myocardial infarction: updated meta-analysis of randomized trials. Clin Res Cardiol. 2010;99:345-357. [pmid: 20221617].
38 Ederle J, Featherstone RL, Brown MM. Randomized controlled trials comparing endarterectomy and endovascular treatment for carotid artery stenosis: a Cochrane systematic review. Stroke. 2009;40:1373-1380. [pmid: 19228850].
39 El-Menyar AA, Al SJ, Holmes DR Jr. Use of drug-eluting stents in patients with coronary artery disease and renal insufficiency. Mayo Clin Proc. 2010;85:165-171. [pmid: 20118392].
40 Ethgen M, Boutron I, Steg PG, Roy C, Ravaud P. Reporting of harm in randomized controlled trials evaluating stents for percutaneous coronary intervention. Trials. 2009;10:29. [pmid: 19413903].
41 Fox KA, Clayton TC, Damman P, et al. Long-term outcome of a routine versus selective invasive strategy in patients with non-ST-segment elevation acute coronary syndrome a meta-analysis of individual patient data. J Am Coll Cardiol. 2010;55:2435-2445. [pmid: 20359842].
42 From AM, Al Badarin FJ, Cha SS, Rihal CS. Percutaneous coronary intervention with drug-eluting stents versus coronary artery bypass surgery for multivessel coronary artery disease: a meta-analysis of data from the ARTS II, CARDia, ERACI III, and SYNTAX studies and systematic review of observational data. EuroIntervention. 2010;6:269-276. [pmid: 20562080].
44 Garg N, Karagiorgos N, Pisimisis GT, et al. Cerebral protection devices reduce periprocedural strokes during carotid angioplasty and stenting: a systematic review of the current literature. J Endovasc Ther. 2009;16:412-427. [pmid: 19702342].
45 Geiger-Gritsch S, Piso B, Guba B, Felder-Puig R. Endovascular deployment of stent graft in the ascending aorta. A systematic review. Chirurg. 2009;80:634-640. [pmid: 19225740].
45 Greenhalgh J, Hockenhull J, Rao N, Dundar Y, Dickson RC, Bagust A. Drug-eluting stents versus bare metal stents for angina or acute coronary syndromes. Cochrane Database Syst Rev. 2010:CD004587. [pmid: 20464732].
46 Groschel K, Schnaudigel S, Pilgram SM, Wasser K, Kastrup A. A systematic review on outcome after stenting for intracranial atherosclerosis. Stroke. 2009;40:e340-e347. [pmid: 19182081].
47 Hakeem A, Khan FM, Bhatti S, et al. Provisional vs. complex stenting strategy for coronary bifurcation lesions: meta-analysis of randomized trials. J Invasive Cardiol. 2009;21:589-595. [pmid: 19901414].
48 Hao PP, Chen YG, Wang XL, Zhang Y. Efficacy and safety of drug-eluting stents in patients with acute ST-segment-elevation myocardial infarction: a meta-analysis of randomized controlled trials. Tex Heart Inst J. 2010;37:516-524. [pmid: 20978561].
49 Hassan AK, Bergheanu SC, Stijnen T, et al. Late stent malapposition risk is higher after drug-eluting stent compared with bare-metal stent implantation and associates with late stent thrombosis. Eur Heart J. 2010;31:1172-1180. [pmid: 19158118].
50 Hlatky MA, Boothroyd DB, Bravata DM, et al. Coronary artery bypass surgery compared with percutaneous coronary interventions for multivessel disease: a collaborative analysis of individual patient data from ten randomised trials. Lancet. 2009;373:1190-1197. [pmid: 19303634].
51 Iijima R, Byrne RA, Dibra A, et al. Drug-eluting stents versus bare-metal stents in diabetic patients with ST-segment elevation acute myocardial infarction: a pooled analysis of individual patient data from seven randomized trials. Rev Esp Cardiol. 2009;62:354-364. [pmid: 19401120].
52 Inaba Y, Chen JA, Mehta N, Bergmann SR. Impact of single or multicentre study design on the results of trials examining the efficacy of adjunctive devices to prevent distal embolisation during acute myocardial infarction. EuroIntervention. 2009;5:375-383. [pmid: 19736164].
53 Jongkind V, Akkersdijk GJ, Yeung KK, Wisselink W. A systematic review of endovascular treatment of extensive aortoiliac occlusive disease. J Vasc Surg. 2010;52:1376-1383. [pmid: 20598474].
54 Jonker FH, Schlosser FJ, Moll FL, et al. Outcomes of thoracic endovascular aortic repair for aortobronchial and aortoesophageal fistulas. J Endovasc Ther. 2009;16:428-440. [pmid: 19702348].
55 Jonker FH, Schlosser FJ, Geirsson A, Sumpio BE, Moll FL, Muhs BE. Endograft collapse after thoracic endovascular aortic repair. J Endovasc Ther. 2010;17:725-734. [pmid: 21142480].
56 Jonker FH, Trimarchi S, Verhagen HJ, Moll FL, Sumpio BE, Muhs BE. Meta-analysis of open versus endovascular repair for ruptured descending thoracic aortic aneurysm. J Vasc Surg. 2010;51:1026-32. 1032. [pmid: 20347700].
57 Joyal D, Filion KB, Eisenberg MJ. Effectiveness and safety of drug-eluting stents in vein grafts: a meta-analysis. Am Heart J. 2010;159:159-169. [pmid: 20152212].
58 Juwana YB, Rasoul S, Ottervanger JP, Suryapranata H. Efficacy and safety of rapamycin as compared to paclitaxel-eluting stents: a meta-analysis. J Invasive Cardiol. 2010;22:312-316. [pmid: 20603502].
59 Kan CD, Lee HL, Luo CY, Yang YJ. The efficacy of aortic stent grafts in the management of mycotic abdominal aortic aneurysm-institute case management with systemic literature comparison. Ann Vasc Surg. 2010;24:433-440. [pmid: 19932948].
60 Karjalainen PP, Biancari F, Ylitalo A, et al. Pooled analysis of trials comparing titanium-nitride-oxide-coated stents with paclitaxel-eluting stents in patients undergoing coronary stenting. J Invasive Cardiol. 2010;22:322-326. [pmid: 20603504].
61 Karkos CD, Harkin DW, Giannakou A, Gerassimidis TS. Mortality after endovascular repair of ruptured abdominal aortic aneurysms: a systematic review and meta-analysis. Arch Surg. 2009;144:770-778. [pmid: 19687383].
62 Kasapis C, Henke PK, Chetcuti SJ, et al. Routine stent implantation vs. percutaneous transluminal angioplasty in femoropopliteal artery disease: a meta-analysis of randomized controlled trials. Eur Heart J. 2009;30:44-55. [pmid: 19028778].
63 Katritsis DG, Siontis GC, Ioannidis JP. Double versus single stenting for coronary bifurcation lesions: a meta-analysis. Circ Cardiovasc Interv. 2009;2:409-415. [pmid: 20031750].
64 Kirtane AJ, Gupta A, Iyengar S, et al. Safety and efficacy of drug-eluting and bare metal stents: comprehensive meta-analysis of randomized trials and observational studies. Circulation. 2009;119:3198-3206. [pmid: 19528338].
65 Koullias GJ, Wheatley GH III. State-of-the-art of hybrid procedures for the aortic arch: a meta-analysis. Ann Thorac Surg. 2010;90:689-697. [pmid: 20667392].
66 Kropman RH, Schrijver AM, Kelder JC, Moll FL, de Vries JP. Clinical outcome of acute leg ischaemia due to thrombosed popliteal artery aneurysm: systematic review of 895 cases. Eur J Vasc Endovasc Surg. 2010;39:452-457. [pmid: 20153667].
67 Lanjewar C, Jolly S, Mehta SR. Effects of aspiration thrombectomy on mortality in patients with acute myocardial infarction undergoing primary percutaneous coronary intervention: a meta-analysis of the randomized trials. Indian Heart J. 2009;61:335-340. [pmid: 20635735].
68 Lee MS, Yang T, Dhoot J, Iqbal Z, Liao H. Meta-analysis of studies comparing coronary artery bypass grafting with drug-eluting stenting in patients with diabetes mellitus and multivessel coronary artery disease. Am J Cardiol. 2010;105:1540-1544. [pmid: 20494658].
69 Lee MS, Yang T, Kandzari DE, Tobis JM, Liao H, Mahmud E. Comparison by meta-analysis of drug-eluting stents and bare metal stents for saphenous vein graft intervention. Am J Cardiol. 2010;105:1076-1082. [pmid: 20381656].
70 Lee MS, Yang T, Dhoot J, Liao H. Meta-analysis of clinical studies comparing coronary artery bypass grafting with percutaneous coronary intervention and drug-eluting stents in patients with unprotected left main coronary artery narrowings. Am J Cardiol. 2010;105:1070-1075. [pmid: 20381655].
71 Li YL, Wan Z, Lu WL, Wang JH. Comparison of sirolimus- and paclitaxel-eluting stents in patients undergoing primary percutaneous coronary intervention for ST-elevation myocardial infarction: a meta-analysis of randomized trials. Clin Cardiol. 2010;33:583-590. [pmid: 20842744].
72 Liu Z, Shi Z, Wang Y, et al. Carotid artery stenting versus carotid endarterectomy: systematic review and meta-analysis. World J Surg. 2009;33:586-596. [pmid: 19127380].
73 Malkawi AH, Hinchliffe RJ, Holt PJ, Loftus IM, Thompson MM. Percutaneous access for endovascular aneurysm repair: a systematic review. Eur J Vasc Endovasc Surg. 2010;39:676-682. [pmid: 20185341].
74 Meier P, Brilakis ES, Corti R, Knapp G, Shishehbor MH, Gurm HS. Drug-eluting versus bare-metal stent for treatment of saphenous vein grafts: a meta-analysis. PLoS One. 2010;5:e11040. [pmid: 20548794].
75 Meier P, Knapp G, Tamhane U, Chaturvedi S, Gurm HS. Short term and intermediate term comparison of endarterectomy versus stenting for carotid artery stenosis: systematic review and meta-analysis of randomised controlled clinical trials. BMJ. 2010;340:c467. [pmid: 20154049].
76 Mustafa ST, Sadat U, Majeed MU, Wong CM, Michaels J, Thomas SM. Endovascular repair of nonruptured thoracic aortic aneurysms: systematic review. Vascular. 2010;18:28-33. [pmid: 20122357].
77 Naik H, White AJ, Chakravarty T, et al. A meta-analysis of 3,773 patients treated with percutaneous coronary intervention or surgery for unprotected left main coronary artery stenosis. JACC Cardiovasc Interv. 2009;2:739-747. [pmid: 19695542].
78 Naylor AR, Mehta Z, Rothwell PM. A systematic review and meta-analysis of 30-day outcomes following staged carotid artery stenting and coronary bypass. Eur J Vasc Endovasc Surg. 2009;37:379-387. [pmid: 19201215].
79 Neyt M, Vinck I, Gewillig M, Van BH. Percutaneous pulmonary and aortic valve insertion in Belgium: going for conditional reimbursement or waiting for further evidence?. Int J Technol Assess Health Care. 2009;25:281-289. [pmid: 19619346].
80 Niccoli G, Ferrante G, Porto I, et al. Coronary bifurcation lesions: to stent one branch or both? A meta-analysis of patients treated with drug eluting stents. Int J Cardiol. 2010;139:80-91. [pmid: 19027969].
81 Nordon IM, Hinchliffe RJ, Holt PJ, Loftus IM, Thompson MM. Modern treatment of juxtarenal abdominal aortic aneurysms with fenestrated endografting and open repair--a systematic review. Eur J Vasc Endovasc Surg. 2009;38:35-41. [pmid: 19346140].
82 Palombo D, Lucertini G, Pane B, Spinella G. Endovascular treatment for ruptured abdominal aortic aneurysm. Review of literature. J Cardiovasc Surg (Torino). 2009;50:611-615. [pmid: 19741576].
83 Pan XH, Zhong WZ, Xiang MX, Xu G, Shan J, Wang JA. Clinical outcomes of serolimus-eluting stents versus bare metal stents in ST-segment elevation myocardial infarction patients: a meta-analysis. Chin Med J (Engl). 2009;122:88-92. [pmid: 19187623].
84 Pan XH, Chen YX, Xiang MX, Xu G, Wang JA. A meta-analysis of randomized trials on clinical outcomes of paclitaxel-eluting stents versus bare-metal stents in ST-segment elevation myocardial infarction patients. J Zhejiang Univ Sci B. 2010;11:754-761. [pmid: 20872982].
85 Pandya SB, Kim YH, Meyers SN, et al. Drug-eluting versus bare-metal stents in unprotected left main coronary artery stenosis a meta-analysis. JACC Cardiovasc Interv. 2010;3:602-611. [pmid: 20630453].
86 Paradis JM, Belisle P, Joseph L, et al. Drug-eluting or bare metal stents for the treatment of saphenous vein graft disease: a Bayesian meta-analysis. Circ Cardiovasc Interv. 2010;3:565-576. [pmid: 21098743].
87 Paraskevas KI, Mikhailidis DP, Veith FJ. Carotid artery stenting may be losing the battle against carotid endarterectomy for the management of symptomatic carotid artery stenosis, but the jury is still out. Vascular. 2009;17:183-189. [pmid: 19698297].
88 Piccolo R, Cassese S, Galasso G, De RR, D'Anna C, Piscione F. Sirolimus- versus paclitaxel-eluting stents in patients with acute myocardial infarction: a meta-analysis of randomized trials. Int J Cardiol. 2011;146:234-236. [pmid: 21067831].
89 Piscione F, Piccolo R, Cassese S, Galasso G, Chiariello M. Clinical impact of sirolimus-eluting stent in ST-segment elevation myocardial infarction: a meta-analysis of randomized clinical trials. Catheter Cardiovasc Interv. 2009;74:323-332. [pmid: 19360858].
90 Piscione F, Piccolo R, Cassese S, et al. Is direct stenting superior to stenting with predilation in patients treated with percutaneous coronary intervention? Results from a meta-analysis of 24 randomised controlled trials. Heart. 2010;96:588-594. [pmid: 20357387].
91 Piscione F, Piccolo R, Cassese S, et al. Effect of drug-eluting stents in patients with acute ST-segment elevation myocardial infarction undergoing percutaneous coronary intervention: a meta-analysis of randomised trials and an adjusted indirect comparison. EuroIntervention. 2010;5:853-860. [pmid: 20142203].
92 Raja SG, Atamanyuk I, Kostolny M, Tsang V. In young patients with rheumatic aortic regurgitation compared to non-rheumatics is a Ross operation associated with increased incidence of autograft failure?. Interact Cardiovasc Thorac Surg. 2010;10:600-604. [pmid: 20103506].
93 Rerkasem K, Rothwell PM. Patch angioplasty versus primary closure for carotid endarterectomy. Cochrane Database Syst Rev. 2009:CD000160. [pmid: 19821267].
94 Rizvi AZ, Murad MH, Fairman RM, Erwin PJ, Montori VM. The effect of left subclavian artery coverage on morbidity and mortality in patients undergoing endovascular thoracic aortic interventions: a systematic review and meta-analysis. J Vasc Surg. 2009;50:1159-1169. [pmid: 19878792].
95 Roffi M, Mukherjee D, Clair DG. Carotid artery stenting vs. endarterectomy. Eur Heart J. 2009;30:2693-2704. [pmid: 19861324].
96 Roukoz H, Bavry AA, Sarkees ML, et al. Comprehensive meta-analysis on drug-eluting stents versus bare-metal stents during extended follow-up. Am J Med. 2009;122:581-10. [pmid: 19486720].
97 Sanchez-Recalde A, Jimenez VS, Moreno R, et al. Safety and efficacy of drug-eluting stents versus bare-metal stents in saphenous vein grafts lesions: a meta-analysis. EuroIntervention. 2010;6:149-160. [pmid: 20542811].
98 Seth A, Serruys PW, Lansky A, et al. A pooled gender based analysis comparing the XIENCE V(R) everolimus-eluting stent and the TAXUS paclitaxel-eluting stent in male and female patients with coronary artery disease, results of the SPIRIT II and SPIRIT III studies: two-year analysis. EuroIntervention. 2010;5:788-794. [pmid: 20142192].
99 Siddiq F, Memon MZ, Vazquez G, Safdar A, Qureshi AI. Comparison between primary angioplasty and stent placement for symptomatic intracranial atherosclerotic disease: meta-analysis of case series. Neurosurgery. 2009;65:1024-1033. [pmid: 19934961].
100 Smout J, Macdonald S, Weir G, Stansby G. Carotid artery stenting: relationship between experience and complication rate. Int J Stroke. 2010;5:477-482. [pmid: 21050404].
101 Steichen O, Amar L, Plouin PF. Primary stenting for atherosclerotic renal artery stenosis. J Vasc Surg. 2010;51:1574-1580. [pmid: 20488331].
102 Takagi H, Kawai N, Umemoto T. Stenting versus coronary artery bypass grafting for unprotected left main coronary artery disease: a meta-analysis of comparative studies. J Thorac Cardiovasc Surg. 2009;137:e54-e57. [pmid: 19154888].
103 Takagi H, Goto SN, Matsui M, Manabe H, Umemoto T. A contemporary meta-analysis of Dacron versus polytetrafluoroethylene grafts for femoropopliteal bypass grafting. J Vasc Surg. 2010;52:232-236. [pmid: 20471778].
104 Takagi H, Matsui M, Umemoto T. Increased late mortality with percutaneous stenting for unprotected left main coronary artery stenosis relative to coronary artery bypass grafting: a meta-analysis of observational studies. J Thorac Cardiovasc Surg. 2010;139:1351-1353. [pmid: 20412967].
105 Testa L, Agostoni P, Vermeersch P, et al. Drug eluting stents versus bare metal stents in the treatment of saphenous vein graft disease: a systematic review and meta-analysis. EuroIntervention. 2010;6:527-536. [pmid: 20884442].
106 Tordoir JH, Bode AS, Peppelenbosch N, van der Sande FM, de Haan MW. Surgical or endovascular repair of thrombosed dialysis vascular access: is there any evidence?. J Vasc Surg. 2009;50:953-956. [pmid: 19786244].
107 Touze E, Trinquart L, Chatellier G, Mas JL. Systematic review of the perioperative risks of stroke or death after carotid angioplasty and stenting. Stroke. 2009;40:e683-e693. [pmid: 19892997].
108 Trikalinos TA, sheikh-Ali AA, Tatsioni A, Nallamothu BK, Kent DM. Percutaneous coronary interventions for non-acute coronary artery disease: a quantitative 20-year synopsis and a network meta-analysis. Lancet. 2009;373:911-918. [pmid: 19286090].
109 Twine CP, Coulston J, Shandall A, McLain AD. Angioplasty versus stenting for superficial femoral artery lesions. Cochrane Database Syst Rev. 2009:CD006767. [pmid: 19370653].
110 Twine CP, McLain AD. Graft type for femoro-popliteal bypass surgery. Cochrane Database Syst Rev. 2010:CD001487. [pmid: 20464717].
111 Uchida T, Popma J, Stone GW, et al. The clinical impact of routine angiographic follow-up in randomized trials of drug-eluting stents: a critical assessment of “oculostenotic” reintervention in patients with intermediate lesions. JACC Cardiovasc Interv. 2010;3:403-411. [pmid: 20398868].
112 Usman AA, Tang GL, Eskandari MK. Metaanalysis of procedural stroke and death among octogenarians: carotid stenting versus carotid endarterectomy. J Am Coll Surg. 2009;208:1124-1131. [pmid: 19476901].
113 van Keulen JW, van PJ, Prokop M, Moll FL, van Herwaarden JA. Dynamics of the aorta before and after endovascular aneurysm repair: a systematic review. Eur J Vasc Endovasc Surg. 2009;38:586-596. [pmid: 19648032].
114 Van BH Neyt M. Safety of percutaneous aortic valve insertion. A systematic review. BMC Cardiovasc Disord. 2009;9:45. [pmid: 19723312].
115 van PJ, Schlosser FJ, Muhs BE, Verhagen HJ, Moll FL, van Herwaarden JA. Oversizing of aortic stent grafts for abdominal aneurysm repair: a systematic review of the benefits and risks. Eur J Vasc Endovasc Surg. 2009;38:42-53. [pmid: 19428273].
116 Wiisanen ME, bdel-Latif A, Mukherjee D, Ziada KM. Drug-eluting stents versus bare-metal stents in saphenous vein graft interventions: a systematic review and meta-analysis. JACC Cardiovasc Interv. 2010;3:1262-1273. [pmid: 21232720].
117 Wijeysundera HC, Nallamothu BK, Krumholz HM, Tu JV, Ko DT. Meta-analysis: effects of percutaneous coronary intervention versus medical therapy on angina relief. Ann Intern Med. 2010;152:370-379. [pmid: 20231568].
118 Xenos ES, Minion DJ, Davenport DL, et al. Endovascular versus open repair for descending thoracic aortic rupture: institutional experience and meta-analysis. Eur J Cardiothorac Surg. 2009;35:282-286. [pmid: 19081731].
119 Xiong J, Jiang B, Guo W, Wang SM, Tong XY. Endovascular stent graft placement in patients with type B aortic dissection: a meta-analysis in China. J Thorac Cardiovasc Surg. 2009;138:865-872. [pmid: 19660348].
120 Yan TD, Cao C, Martens-Nielsen J, et al. Transcatheter aortic valve implantation for high-risk patients with severe aortic stenosis: A systematic review. J Thorac Cardiovasc Surg. 2010;139:1519-1528. [pmid: 19846124].
121 Yang Z, Han G, Wu Q, et al. Patency and clinical outcomes of transjugular intrahepatic portosystemic shunt with polytetrafluoroethylene-covered stents versus bare stents: a meta-analysis. J Gastroenterol Hepatol. 2010;25:1718-1725. [pmid: 21039832].
122 Zhang F, Dong L, Ge J. Simple versus complex stenting strategy for coronary artery bifurcation lesions in the drug-eluting stent era: a meta-analysis of randomised trials. Heart. 2009;95:1676-1681. [pmid: 19643768].
123 Zhang F, Dong L, Ge J. Meta-analysis of five randomized clinical trials comparing sirolimus- versus paclitaxel-eluting stents in patients with diabetes mellitus. Am J Cardiol. 2010;105:64-68. [pmid: 20102892].
124 Zhang F, Dong L, Qian J, Ge J. Clinical safety and efficacy of everolimus-eluting stents compared to paclitaxel-eluting stents in patients with coronary artery disease. Ann Med. 2011;43:75-79. [pmid: 21171912].

## Orthopedic

1 Andersson D, Samuelsson K, Karlsson J. Treatment of anterior cruciate ligament injuries with special reference to surgical technique and rehabilitation: an assessment of randomized controlled trials. Arthroscopy. 2009;25:653-685. [pmid: 19501297].
2 Bartels RH, Donk R, Verbeek AL. No justification for cervical disk prostheses in clinical practice: a meta-analysis of randomized controlled trials. Neurosurgery. 2010;66:1153-1160. [pmid: 20421840].
3 Fekete TF, Porchet F. Overview of disc arthroplasty-past, present and future. Acta Neurochir (Wien). 2010;152:393-404. [pmid: 19844656].
4 Giannoudis PV, Papakostidis C, Kouvidis G, Kanakaris NK. The role of plating in the operative treatment of severe open tibial fractures: a systematic review. Int Orthop. 2009;33:19-26. [pmid: 17786444].
5 Han X, Zhu Y, Cui C, Wu Y. A meta-analysis of circumferential fusion versus instrumented posterolateral fusion in the lumbar spine. Spine (Phila Pa 1976). 2009;34:E618-E625. [pmid: 19644321].
6 Hicks JM, Singla A, Shen FH, Arlet V. Complications of pedicle screw fixation in scoliosis surgery: a systematic review. Spine (Phila Pa 1976). 2010;35:E465-E470. [pmid: 20473117].
7 Hoang-Kim A, Scott J, Micera G, Orsini R, Moroni A. Functional assessment in patients with osteoporotic wrist fractures treated with external fixation: a review of randomized trials. Arch Orthop Trauma Surg. 2009;129:105-111. [pmid: 18560856].
8 Kuzyk PR, Bhandari M, McKee MD, Russell TA, Schemitsch EH. Intramedullary versus extramedullary fixation for subtrochanteric femur fractures. J Orthop Trauma. 2009;23:465-470. [pmid: 19550236].
9 Modi CS, Ho K, Smith CD, Boer R, Turner SM. Dynamic and static external fixation for distal radius fractures--a systematic review. Injury. 2010;41:1006-1011. [pmid: 20338565].
10 Regev E, Shiff JS, Kiss A, Fialkov JA. Internal fixation of mandibular angle fractures: a meta-analysis. Plast Reconstr Surg. 2010;125:1753-1760. [pmid: 20517101].
11 Saithna A. The influence of hydroxyapatite coating of external fixator pins on pin loosening and pin track infection: a systematic review. Injury. 2010;41:128-132. [pmid: 19486974].
12 Schepers T, Patka P. Treatment of displaced intra-articular calcaneal fractures by ligamentotaxis: current concepts' review. Arch Orthop Trauma Surg. 2009;129:1677-1683. [pmid: 19543741].
13 Shen C, Jiang SD, Jiang LS, Dai LY. Bioabsorbable versus metallic interference screw fixation in anterior cruciate ligament reconstruction: a meta-analysis of randomized controlled trials. Arthroscopy. 2010;26:705-713. [pmid: 20434671].
14 van den Eerenbeemt KD, Ostelo RW, van Royen BJ, Peul WC, van Tulder MW. Total disc replacement surgery for symptomatic degenerative lumbar disc disease: a systematic review of the literature. Eur Spine J. 2010;19:1262-1280. [pmid: 20508954].
15 Verma R, Krishan S, Haendlmayer K, Mohsen A. Functional outcome of computer-assisted spinal pedicle screw placement: a systematic review and meta-analysis of 23 studies including 5,992 pedicle screws. Eur Spine J. 2010;19:370-375. [pmid: 20052504].
16 Winegar CD, Lawrence JP, Friel BC, et al. A systematic review of occipital cervical fusion: techniques and outcomes. J Neurosurg Spine. 2010;13:5-16. [pmid: 20594011].

## Skin Grafts

1 Bergin SM, Wraight P. Silver based wound dressings and topical agents for treating diabetic foot ulcers. Cochrane Database Syst Rev. 2006:CD005082. [pmid: 16437516].
2 Blozik E, Scherer M. Skin replacement therapies for diabetic foot ulcers: systematic review and meta-analysis. Diabetes Care. 2008;31:693-694. [pmid: 18162495].
3 Chaby G, Senet P, Vaneau M, et al. Dressings for acute and chronic wounds: a systematic review. Arch Dermatol. 2007;143:1297-1304. [pmid: 17938344].
4 Hinchliffe RJ, Valk GD, Apelqvist J, et al. A systematic review of the effectiveness of interventions to enhance the healing of chronic ulcers of the foot in diabetes. Diabetes Metab Res Rev. Suppl 1. 2008;24:S119-S144. [pmid: 18442185].
5 Knight BC, Tait WF. Dacron patch infection following carotid endarterectomy: a systematic review of the literature. Eur J Vasc Endovasc Surg. 2009;37:140-148. [pmid: 19041268].
6 Langer A, Rogowski W. Systematic review of economic evaluations of human cell-derived wound care products for the treatment of venous leg and diabetic foot ulcers. BMC Health Serv Res. 2009;9:115. [pmid: 19591680].
7 Pham C, Greenwood J, Cleland H, Woodruff P, Maddern G. Bioengineered skin substitutes for the management of burns: a systematic review. Burns. 2007;33:946-957. [pmid: 17825993].
8 Voineskos SH, Ayeni OA, McKnight L, Thoma A. Systematic review of skin graft donor-site dressings. Plast Reconstr Surg. 2009;124:298-306. [pmid: 19568092].

## Neurostimulators

1 Andrade P, Carrillo-Ruiz JD, Jimenez F. A systematic review of the efficacy of globus pallidus stimulation in the treatment of Parkinson's disease. J Clin Neurosci. 2009;16:877-881. [pmid: 19398341].
2 Andrade P, Noblesse LH, Temel Y, et al. Neurostimulatory and ablative treatment options in major depressive disorder: a systematic review. Acta Neurochir (Wien). 2010;152:565-577. [pmid: 20101419].
3 Andrews C, viles-Olmos I, Hariz M, Foltynie T. Which patients with dystonia benefit from deep brain stimulation? A metaregression of individual patient outcomes. J Neurol Neurosurg Psychiatry. 2010;81:1383-1389. [pmid: 20841370].
4 Benabid AL, Chabardes S, Mitrofanis J, Pollak P. Deep brain stimulation of the subthalamic nucleus for the treatment of Parkinson's disease. Lancet Neurol. 2009;8:67-81. [pmid: 19081516].
5 Clarke CE, Worth P, Grosset D, Stewart D. Systematic review of apomorphine infusion, levodopa infusion and deep brain stimulation in advanced Parkinson's disease. Parkinsonism Relat Disord. 2009;15:728-741. [pmid: 19805000].
6 Flora ED, Perera CL, Cameron AL, Maddern GJ. Deep brain stimulation for essential tremor: a systematic review. Mov Disord. 2010;25:1550-1559. [pmid: 20623768].
7 Fontaine D, Hamani C, Lozano A. Efficacy and safety of motor cortex stimulation for chronic neuropathic pain: critical review of the literature. J Neurosurg. 2009;110:251-256. [pmid: 18991496].
8 Fountas KN, Kapsalaki E, Hadjigeorgiou G. Cerebellar stimulation in the management of medically intractable epilepsy: a systematic and critical review. Neurosurg Focus. 2010;29:E8. [pmid: 20672925].
9 Georgiopoulos M, Katsakiori P, Kefalopoulou Z, Ellul J, Chroni E, Constantoyannis C. Vegetative state and minimally conscious state: a review of the therapeutic interventions. Stereotact Funct Neurosurg. 2010;88:199-207. [pmid: 20460949].
10 Halpern CH, Rick JH, Danish SF, Grossman M, Baltuch GH. Cognition following bilateral deep brain stimulation surgery of the subthalamic nucleus for Parkinson's disease. Int J Geriatr Psychiatry. 2009;24:443-451. [pmid: 19016252].
11 Kennedy SH, Milev R, Giacobbe P, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults. IV. Neurostimulation therapies. J Affect Disord. Suppl 1. 2009;117:S44-S53. [pmid: 19656575].
12 Lakhan SE, Callaway E. Deep brain stimulation for obsessive-compulsive disorder and treatment-resistant depression: systematic review. BMC Res Notes. 2010;3:60. [pmid: 20202203].
13 Previnaire JG, Nguyen JP, Perrouin-Verbe B, Fattal C. Chronic neuropathic pain in spinal cord injury: efficiency of deep brain and motor cortex stimulation therapies for neuropathic pain in spinal cord injury patients. Ann Phys Rehabil Med. 2009;52:188-193. [pmid: 19909709].
14 St George RJ, Nutt JG, Burchiel KJ, Horak FB. A meta-regression of the long-term effects of deep brain stimulation on balance and gait in PD. Neurology. 2010;75:1292-1299. [pmid: 20921515].