# Search Strategy

1. defibrillators, implantable/ or pacemaker, artificial/ or cardiac resynchronization therapy devices/ or heart, artificial/ or heart-assist devices/ or Heart Valve Prosthesis/ (26457)
2. (defibrillator* or pacemaker* or cardiac resynchronization therapy device* or artificial heart or heart assist device* or heart valve prosthe*).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (42310)
3. implantable neurostimulators/ or neural prostheses/ or auditory brain stem implants/ or cochlear implants/ or Deep Brain Stimulation/ (5661)
4. (neurostimulat* or neural prosthe* or brain stem implant* or cochlear implant* or deep brain stimulat*).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (10382)
5. “prostheses and implants”/ or absorbable implants/ or artificial limbs/ or bioprosthesis/ or orthopedic fixation devices/ or external fixators/ or internal fixators/ (28244)
6. (artificial limb* or bioprosthe* or orthopedic fixation device* or external fixator* or internal fixator*).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (13888)
7. blood vessel prosthesis/ or stents/ or drug-eluting stents/ (40837)
8. (blood vessel prosthe* or stent* or drug-eluting stent*).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (57375)
9. (skin graft* or wound care or skin replac*).mp. or Skin, Artificial/ [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (9349)
10. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 (142446)
11. meta-analysis.pt. (24009)
12. meta-analysis.sh. (24009)
13. (meta-analys$ or meta analys$ or metaanalys$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (43475)
14. (systematic$ adj9 review$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (29696)
15. (systematic$ adj9 overview$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (615)
16. (quantitativ$ adj9 review$).mp. (2098)
17. (quantitativ$ adj9 overview$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (161)
18. (quantitativ$ adj9 synthesis$).mp. (907)
19. (methodologic$ adj9 review$).mp. (3153)
20. (methodologic$ adj9 overview$).mp. (173)
21. (integrative research review$ or research integration).mp. (48)
22. 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 (67875)
23. 10 and 22 (1385)
24. limit 23 to yr=“2009 - 2010” (467)