# References

1 Ip S, Hadar N, Keefe S, et al. A Web-based archive of systematic review data. Syst Rev. 2012;1(1):15. [pmid: 22588052].
2 Erinoff E. Feasibility study of a wiki collaboration platform for systematic review. Slide Presentation from the AHRQ 2009 Annual Conference (Text Version). December 2009. Agency for Healthcare Research and Quality. Rockville, MD. www.ahrq.gov/about/annualconf09/erinoff.htm.