# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

## Scientific Advisory Committee Members

Mohammed Ansari, M.B.B.S., M.Med.Sc.

University of Ottawa Evidence-based Practice Center

Kay Dickersin, Ph.D.

Johns Hopkins University

Mark Helfand, M.D., M.S., M.P.H.

Oregon Evidence-based Practice Center

Nicholas C. Ide, M.S.

National Library of Medicine

David Moher, Ph.D.

University of Ottawa Evidence-based Practice Center

Amanda Sowden, Ph.D.

Center for Research and Dissemination

York University, UK

Lesley Stewart, Ph.D.

Center for Research and Dissemination

York University, UK

Deborah Zarin, M.D.

National Library of Medicine

### Ex officio

Stephanie Chang, M.D., M.P.H.

Agency for Healthcare Research and Quality

Mary P. Nix, M.S., M.T. (ASCP), S.B.B.

Agency for Healthcare Research and Quality

## Consultants

Susan Merewitz, J.D.

Legal Consultant

Ida Sim, M.D., Ph.D.

UCSF School of Medicine

## Agency for Healthcare Research and Quality

Stephanie Chang, M.D., M.P.H.

Evidence-based Practice Center Program

Agency for Healthcare Research and Quality

540 Gaither Road

Rockville, MD 20850

Mary Nix, M.S., M.T. (ASCP), S.B.B.

Center for Outcomes and Evidence

Agency for Healthcare Research and Quality

540 Gaither Road

Rockville, MD 20850

Yen-pin Chiang, Ph.D.

Center for Outcomes and Evidence

Agency for Healthcare Research and Quality

Center for Outcomes and Evidence

540 Gaither Road

Rockville, MD 20850