# Conclusion

Herein, we have discussed a number of issues with regards to the future administration of the SRDR. We sketched out two possible organizational structures based on probable funding scenarios for the repository, and examined a proposed multipronged approach to ensuring the quality of deposited data.

AHRQ has invested in the development of the SRDR for the past 2 years; however, its long-term funding and permanent home have yet to be determined. Therefore, many of the issues raised in this report remain in flux, and their eventual resolution will depend greatly on the events of the upcoming year, as well as on the experience gained as the repository transitions into routine use. Similarly, though we have attempted to be thorough in laying out the relevant issues to be resolved, others may become apparent as development progresses.

The Tufts EPC has continued to refine the SRDR and expand its features and functionality. In addition, we plan to form a new advisory panel and solicit further feedback as the repository becomes more widely used, seeking a greater range of stakeholder input. In addition to the relevant Federal agencies, we expect representatives from other EPCs and the Cochrane Collaboration, as well as other relevant health care organizations, such as Kaiser-Permanente, to assist with further policy development.

It is our hope that by engaging the wider stakeholder community—consumers, payers, researchers, and governments alike—we can foster a collaborative environment that will enable this repository to grow into a valuable and permanent resource of benefit to all.