# Results

The articles were chosen by language only. We did not consider geographic distribution when selecting articles. All Chinese, German, and Japanese articles were from China, Germany, and Japan, respectively. The French articles were from France (5), Canada (3), Tunisia (1), and Turkey (1); and the Spanish articles were from Spain (5), Argentina (3), Colombia (1), and Mexico (1). The Chinese articles were all published in simplified Chinese. Other characteristics of the included studies are presented in Table 2.

Table 2 Characteristics of included trials

Language | Publication Dates (N) | Clinical Domains / Populations | Intervention Types (N) | Outcome Types (N)
Chinese | 2004 (1) | Colonoscopy | Behavior (1) | Dichotomous (8)
Chinese | 2008 (3) | Dementia | CAM (4) | Continuous (9)
Chinese | 2009 (1) | Gynecologic surgery | Dxic test agent (1)
Chinese | 2010 (4) | Hepatocellular carcinoma | Drug (4)
Chinese | 2011 (1) | Lung cancer
Chinese | | Myopia
Chinese | | Nocturia
Chinese | | Parkinson's Disease
Chinese | | Premature LBW infants
Chinese | | Pulmonary surgery
French | 1993 (1) | Acute sinusitis | Counseling (1) | Dichotomous (7)
French | 1994 (1) | Allergic conjunctivitis | CAM (1) | Continuous (8)
French | 1996 (1) | Helicobacter pylori infection | Diet (1)
French | 1997 (1) | Hepatitis C | Drug (7)
French | 2000 (1) | Homeopathy adverse effect
French | 2006 (2) | Hypercholesterolemia
French | 2008 (2) | Hypertension
French | 2009 (1) | Obstetrics
French | | Pterygium (ophthalmology)
French | | Refraction (ophthalmology)
German | 2002 (1) | Anesthesia | CAM (1) | Dichotomous (7)
German | 2005 (1) | Cataract surgery | Counseling (1) | Continuous (10)
German | 2007 (2) | Chronic prostatitis | Device (3)
German | 2008 (2) | Hernia surgery | Drug (3)
German | 2009 (1) | Keratoplasty (ophthalmology) | Exercise (1)
German | 2010 (2) | Knee arthroscopic surgery | Surgery (1)
German | 2012 (1) | Scar formation
German | | Schizophrenia
German | | Total hip replacement
German | | Whiplash
Japanese | 2001 (2) | Cardiac function | CAM (1) | Dichotomous (5)
Japanese | 2002 (1) | Colorectal cancer | Counseling (1) | Continuous (7)
Japanese | 2004 (2) | Diabetes mellitus education | Drug (4)
Japanese | 2008 (1) | Diabetes mellitus prevention | Education (3)
Japanese | 2009 (2) | Fungal prophylaxis (oncology), 2 studies | Formulation (1)
Japanese | 2010 (2) | Gynecologic laparoscopic surgery
Japanese | | Hypercholesterolemia
Japanese | | Smoking cessation
Japanese | | Tinea pedis
Spanish | 2002 (1) | Gerontology, enteral feedings | Anesthesia (1) | Dichotomous (5)
Spanish | 2003 (1) | Hypertension | Drug (5) | Continuous (7)
Spanish | 2005 (1) | Intracranial hypertension | Education (1)
Spanish | 2006 (1) | Malaria | Nutrition (2)
Spanish | 2008 (1) | Molar extraction (dental) | Procedure (1)
Spanish | 2009 (2) | Neonatology, 2 studies
Spanish | 2010 (3) | Obesity, 2 studies
Spanish | | Oral candidiasis
English | 1997 (1) | Anesthesia, bowel surgery | Blood products (1) | Dichotomous (6)
English | 2002 (1) | Cardiovascular risk factors | Drugs (4) | Continuous (9)
English | 2003 (1) | Cerebral ischemia | Exercise (1)
English | 2005 (1) | Cleft lip and palate | Nutrition (3)
English | 2007 (1) | Diabetes mellitus, type 2 | Procedure (1)
English | 2008 (1) | Macular degeneration
English | 2009 (1) | Menopause
English | 2010 (2) | Nutrition, micronutrients
English | 2011 (1) | Parkinson's disease
English | | Sickle cell anemia

CAM = complementary and alternative medicine; Dxic = diagnostic; LBW = low birth weight; N = number of articles.

Among the 15 investigators who extracted data from original language articles (10 investigators) and translated and English articles (9 investigators), 11 are M.D. or Ph.D. (or both) researchers, 2 are research associates (or equivalent), and 2 are medical residents with research experience. The median duration of experience with data extraction was 5 years, with 4 extractors having 10 to 14 years of experience, and 4 having less than 1 year of experience. Six of the investigators have participated in more than 20 systematic reviews, 1 has participated in 11 to 20 reviews, 5 in 6 to 10 reviews, and 3 in 5 or fewer reviews. Eight investigators have extracted more than 100 studies, 4 have extracted 51 to 100 studies, and 3 have extracted 50 or fewer articles. Nine investigators judged that they have a lot of comfort with the Cochrane risk of bias questions, 4 had moderate comfort, 1 had little comfort, and 1 had no experience with assessing risk of bias. The medical resident with no prior systematic review experience extracted 10 original language articles. She had oversight and assistance from the director of the EPC she was affiliated with.

## Article Translation

The length of time required to translate articles ranged from 5 minutes (2 of 50 articles) to about 1 hour (11 articles) for most articles; 2 articles took more than 1 hour. Excluding the time taken for the latter two articles, the average time to translate was about 30 minutes. The time-for-translation distributions varied by language (Table 3), with Spanish articles being the quickest to translate and Chinese articles taking longest.

Table 3 Translation time (minutes), by language

Articles^*^: | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | Median
European
French | 20 | 30 | 30 | 30 | 30 | 30 | 30 | 30 | 45 | 60 | 30
German | 15 | 20 | 20 | 25 | 30 | 30 | 30 | 30 | 40 | 240 | 30
Spanish | 10 | 10 | 10 | 10 | 15 | 15 | 15 | 15 | 20 | 20 | 15
Asian
Chinese | 60 | 60 | 60 | 60 | 60 | 60 | 60 | 60 | 60 | 120 | 60
Japanese | 5 | 5 | 20 | 20 | 20 | 20 | 30 | 30 | 30 | 60 | 20

* For each language, the approximate duration of time, in minutes, for translation of each article is listed, sorted from shortest to longest time.

In general, the European- and Japanese-language articles could be translated automatically from their PDF or HTML files. These texts were then copied to Word documents after translation. However, the ease of translation was largely related to the file and text types used by the journals and whether Google Translate could read these directly or not.

The extra time required to translate the other articles consisted mainly of iteratively copying blocks of text (paragraphs or columns) from the article into the Google Translate Web site and then copying the translated text into Word documents. This often involved using the appropriate alphabet from the original language, and removing false line breaks, hyphens, and unnecessary spaces. We discovered (and were informed by the Chinese speakers among us) that we needed to remove false line breaks (artifactual breaks not at the end of sentences) in the Asian language articles to allow meaningful translation. Translation of tables was frequently very time consuming as it required a large number of translations of individual row and column headers and formatting in the translated Word document.

For numerous articles, particularly those in the Chinese language, Google Translate could directly translate the PDF or HTML file, but the resulting file was unreadable because of heavily overlapping text across columns; therefore, manual copying and pasting of these articles had to be done. Since Google Translate attempted to maintain the original formatting and because some written languages are much more compact than English, the English text ran from one column to the next, overlapping the text in the second column.

Other issues we encountered included that one Spanish PDF could not be read originally but could after it was saved as a TIFF file from which another PDF was created; one German article required removing multiple instances of “¬” (an optional hyphen) before translation could succeed. One German article was clearly an outlier in that it took almost 4 hours to translate because of the poor quality of the original file. When text from this particular article was copied and pasted into either Google Translate or Microsoft Word, the copied text included spaces randomly placed within most of the words. Because the quality of the translated text was greatly improved after removing these superfluous spaces, this extra step was undertaken. One Chinese article took almost 2 hours because the non-Chinese characters (such as words and numbers) within the file were copied to gibberish and had to be manually retyped for proper translation.

## Data Extraction From Translated Articles

The assessment by the English language data extractors was that extraction from translated articles generally took more time than extraction from an equivalent English-language article would have taken. Extractors were asked to estimate how much additional time they spent on each translated article compared with the time they likely would have spent with a comparable English article (Table 4). For Spanish articles, extractors estimated that 56 percent of articles took less than 5 additional minutes to extract, and all but one article took up to 30 additional minutes to extract. Extraction of other translated articles generally took longer. Between 60 and 75 percent of other language articles were estimated to take between 6 and 30 additional minutes to extract, with generally most of the remaining articles requiring more than 30 minutes extra. Anecdotally, for some Chinese articles the translation was so poor that little could be extracted, which resulted in little time being required to extract the article.

Table 4 Estimated additional time required compared to extraction of a similar English article

Extra Time | Chinese Percent (n) | French Percent (n) | German Percent (n) | Japanese Percent (n) | Spanish Percent (n) | Overall Percent (n)
<5 min | 20% (4) | 5% (1) | 20% (4) | 5% (1) | 56% (10) | 21% (20)
6-30 min | 70% (14) | 68% (13) | 60% (12) | 75% (15) | 39% (7) | 63% (61)
>30 min | 10% (2) | 26% (5) | 20% (4) | 20% (4) | 6% (1) | 16% (16)

Extractors were also asked to assess their level of confidence in the translation of the articles (Table 5). Extractors had strong confidence for the majority (60 percent) of Spanish articles. Confidence in the translation of other language articles was generally moderate with 65 to about 70 percent of articles across languages.

Table 5 Confidence in accuracy and completeness of the translation

Confidence | Chinese Percent (n) | French^*^ Percent (n) | German Percent (n) | Japanese Percent (n) | Spanish Percent (n) | Overall^*^ Percent (n)
Strong | 10% (2) | 5% (1) | 15% (3) | 5% (1) | 60% (12) | 26% (26)
Moderate | 65% (13) | 65% (13) | 65% (13) | 60% (12) | 25% (5) | 55% (55)
Little | 25% (5) | 25% (5) | 20% (4) | 35% (7) | 15% (3) | 18% (18)

* 1 extractor did not rate confidence level for 1 article.

Table 6 provides some examples of unintelligible translations collected by the extractors. Additional issues included lack of translation of figures and some tables, blocks of gibberish, and completely untranslated text.

Table 6 Examples of poor translation, by language

Language | Translated Text
Chinese | R group of 33 cases, due to the three cases of epidural catheter prolapse were excluded, the remaining 18 cases analgesia is effective, 12 cases of analgesia is not valid Of CO2 group in check after 1, 3 and 6h abdominal pain mean VAS scores were significantly lower than the air group (all P <0.01, Figure 2), check the inter-24h two groups remain statistically different (P <0.05, Figure 2). stabbed five tomato feed rate of 2 per week <8mL/kg the number of night enuresis ≥ 1 or ≥ 7 times / week the main points to take Baihui, the Court of God, Ojo. Acupoints with the disease: liver and kidney deficiency with liver Yu, Shenshu; phlegm blocking orifices with Zhong Wan, Hong Leong; deficiency with the sea air. PD duration â‰¤ 15 years. 2009 in my inpatient children of low birth weight (less than 37 weeks gestational age at birth and neonatal birth weight less than 2500g) as the object of study, except for the digestive tract abnormalities, in line with the conditions60 cases were randomly divided into […] Probiotic treatment groups at the beginning of the gastrointestinal tract in children, while giving the Golden Bifid feeding treatment, each 0.25g, 2 times / day, oral or nasal administration, to the increase of milk when total parenteral nutrition is discontinued , premature children total parenteral nutrition and fluid requirements with reference to calorie “practical neonatology” (3rd edition) in the recommended amount
French | I1 important to note that this assessment does not address the practice of individual physicians each of the media but rather on an overall profile of theirapproach and more specifically 1'HTA on the proportion of hypertensive patients who have reached a satisfactory control their hypertension. a single pregnancy by presenting the evolutionary eutrophic tion of the top and run over 36 weeks amenorrhea (SA) plus zero days treatment may interfere in the convenience store (anti-depressant), rather than.
German | A patient with intrastromal corneal ring was excluded from the study because he suffered by a missile blast with Fadenruptur graft and bending of the corneal ring. auch here should be 3 – diclofenac 50 It was only to patients, each of two same age, in terms of localization, incision depth and the used suture scars showed equivalent or at least had a 20 cm long scar and Pa ¬, who stood so close to release that no meeting date has been more identified. standard therapy using HWSKrawatte The randomization of patients was based on randomisation. “instead gehabter fracture” Intervention” and was “Shamgruppe
Japanese | Terubinafinkurimu hydrochloride (A): 1g of terbinafine hydrochloride cream containing 10mg. Cream base (B): cream base only brewed Results Fruit Gram character tendency of the element 5 Blinding was not possible to be so different, surgery adjuvant therapy for patients with oral cancer resection for CR doxifluridine
Spanish | AI discharge five patients from group thiopental had died and eight in the group of pentobarbital- barbital (P0, 16). At six months remained the super- EXPERIENCE. Patients with affeccio- of the skin that could prevent serious evaluation therapy

## Comparison of Extractions From Translated and Original Articles

Table 7 displays the adjusted percentage of correct extractions per language, including English, and per analyzed extraction item; the percentages are adjusted for individuals' likelihood of correctly extracting English articles. To recap, the reference standards for English-language articles were the consensus extraction across all researchers or between the senior investigators; the reference standards for translated articles were the double data extraction results from original language extractions. The extraction items are clustered by study domain (study design, intervention description data including the number of participants randomized, outcome descriptions, and results). The specific extraction questions are described in Appendix A. In general, across languages the agreement between the extractors and the reference standards for each article (from consensus in English and from double-extracted original language articles in other languages) was greater for design and intervention domain items than for outcome descriptions and study results. In particular, extractors did relatively poorly extracting which outcomes from a given list were reported in the study and in extracting net differences (or equivalent results) and their standard errors for continuous outcomes.

Table 7 Percentage of correct extractions, per item and language, adjusted for individual's likelihood of correctly extracting the same data item from English articles

Domain | Extraction Item | English | Chinese | French | German | Japanese | Spanish
Design | Inclusion criteria | 99 | 99 | 100 | 98 | 93 | 99
Design | Exclusion criteria | 98 | 97 | 100 | 70 | 79 | 97
Design | Funding source | 93 | 100 | 86 | 99 | 99 | 35
Design | No. centers | 86 | 97 | 85 | 87 | 51 | 87
Design | Followup duration | 88 | 79 | 41 | 82 | 84 | 96
Design | Randomization technique | 95 | 87 | 82 | 78 | 89 | 93
Design | Allocation concealment method | 93^*^ | 100^*^ | 85^*^ | 100^*^ | 80^*^ | 85^*^
Design | Intention-to-treat analysis | 98^*^ | 100^*^ | 90^*^ | 95^*^ | 80^*^ | 75^*^
Design | Power calculation | 99 | 95 | 74 | 97 | 100 | 98
Design | Subject blinding (explicit) | 93 | 100 | 98 | 97 | 90 | 78
Design | Caregiver blinding (explicit) | 92 | 100 | 95 | 96 | 98 | 98
Design | Outcome assessor blinding (explicit) | 89 | 88 | 91 | 97 | 96 | 90
Design | Double blinded | 94^*^ | 100^*^ | 100^*^ | 95^*^ | 100^*^ | 95^*^
Design | Single blinded | 99^*^ | 100^*^ | 95^*^ | 100^*^ | 90^*^ | 100^*^
Design | Outcomes reported^†^ | 63 | 36 | 43 | 12 | 5 | 21
Design | No outcomes missed^‡^ | 75 | 80 | 74 | 13 | 11 | 31
Design | No extra outcomes added^**^ | 96 | 90 | 82 | 99 | 96 | 99
Intervention | Dose (of all interventions) | 82 | 88 | 97 | 79 | 91 | 81
Intervention | Frequency (of all interventions) | 87 | 74 | 87 | 86 | 75 | 83
Intervention | Route (of all interventions) | 100 | 99 | 100 | 100 | 100 | 100
Intervention | Duration (of all interventions) | 96 | 28 | 75 | 66 | 88 | 77
Intervention | No. randomized (for all interventions) | 71 | 97 | 91 | 97 | 82 | 89
Outcome | Description | 87 | 45 | 51 | 42 | 75 | 98
Results | No. analyzed (per intervention) | 100 | 96 | 98 | 98 | 94 | 98
Results | Mean or median reported^††^ | 94^*^ | 100^*^ | 100^*^ | 84^*^ | 71^*^ | 100^*^
Results | Net difference^††^ | 81 | 28 | 15 | 73 | 67 | 60
Results | Standard error of net difference^††^ | 81 | 38 | 15 | 64 | 56 | 71
Results | No. events (counts) or odds ratio^‡‡^ | 99 | 98 | 86 | 37 | 47 | 94
Results | Reported P value of difference or odds ratio | 93 | 30 | 81 | 73 | 21 | 73
Overall^***^ | % items ≥98% correct | 30 | 41 | 26 | 22 | 19 | 30
Overall | % items ≥91% correct | 63 | 59 | 37 | 48 | 30 | 48
Overall | % items ≥76% correct | 93 | 74 | 74 | 70 | 67 | 78
Overall | % items ≥51% correct | 100 | 78 | 85 | 89 | 89 | 93
Overall | % items ≤50% correct | 0 | 22 | 15 | 11 | 11 | 7

Shading of cells matches reported percentages

98-100% correct 100^th^ percentile) | 91-97% correct 72^nd^ percentile) | 76-90% correct 50^th^ percentile) | 51-75% correct 24^th^ percentile) | ≤50% correct 11^th^ percentile).

* Crude (unadjusted) percentage.

† From a list of proffered outcomes, there was exact agreement as to which were reported in the study.

‡ No outcomes found in the original article were missed from the translated article. This item is excluded from the overall percentages of items correct at the bottom of the table.

** No outcomes not found in the original article were added from the translated article. This item is excluded from the overall percentages of items correct at the bottom of the table.

†† For continuous outcomes.

‡‡ For dichotomous outcomes.

*** The five “Overall” rows display the percentage of the 29 items (not the individual extractions), per language, that were each extracted correctly the given percentage of the time (e.g., 30% of the English items were extracted correctly 98-100% of the time). Note that the final two rows, by definition, sum to 100%.

Translated Chinese articles yielded the largest percentage of items (22 percent) incorrectly extracted by more than half the extractors, although Chinese articles also yielded the largest percentage of items (41 percent) extracted correctly by more than 98 percent of the extractors (including English article extractions). However, translated Chinese articles had particularly lower likelihoods of correct extractions for the important extraction items about descriptions of the interventions, the outcomes, and the results. In contrast, extractors of translated Spanish articles had relatively high likelihoods of extracting items correctly except, in comparison with English, for results data. For Spanish, only 7 percent of items had less than 50 percent correct extractions, including funding source and identifying reported outcomes. Extractions of other translated language articles yielded similar patterns as for translated Chinese articles, but with generally higher rates of correct extractions. In particular, identifying reported outcomes and extracting results were more likely to be incorrect.

Table 8 displays the adjusted odds ratios between translated and English articles of correctly extracting individual items (the odds of correct extractions from translated articles versus the odds of correct extractions from English articles, adjusted for each researcher's likelihood of correctly extracting the English data items). Of note, it was not uncommon that the odds of correctly extracting individual items from the translated articles were greater than the odds of doing so from the 10 extracted English articles. All odds ratios of 1 or greater were analyzed as being equivalent to perfect agreement. Overall, the pattern of odds ratios of adjusted odds ratios of correct answers compared with English across items and languages (Table 8) was similar to the pattern of adjusted percentages (Table 7). It highlights that for all translated languages except Spanish, extractors were statistically significantly more likely to extract incorrect data for outcome description and results from translated articles than from English articles. Similarly, the likelihood of missing reported outcomes was higher from translated articles, significantly so for German, Japanese, and Spanish articles. The seeming discrepancy between Tables 7 and 8 in the results for duration of interventions (with the “Intervention” domain) is due to the near 100 percent accuracy for all languages and thus small numbers of incorrect extractions (e.g., 2 or 4 percent versus 0 percent).

Table 8 Odds ratios (confidence intervals) compared with English of correct extractions, adjusted for individual's likelihood of correctly extracting the same data item from English articles

Domain | Extraction Item | Chinese | French | German | Japanese | Spanish
Design | Inclusion criteria | 1.9 (0.1, >5) | 3.0 (0.2, >5) | 0.5 (<0.1, >5) | 0.1 (<0.1, 1.4) | 0.8 (0.1, >5)
Design | Exclusion criteria | 0.6 (<0.1, >5) | >5 (<0.1, >5) | <0.1 (<0.1, 0.7) | <0.1 (<0.1, 1.2) | 0.7 (<0.1, >5)
Design | Funding source | >5 (0.2, >5) | 0.5 (<0.1, >5) | >5 (0.2, >5) | >5 (0.2, >5) | <0.1 (<0.1, 1.0)
Design | No. centers | 4.7 (0.4, >5) | 0.9 (0.2, >5) | 1.1 (0.2, >5) | 0.2 (<0.1, 0.9) | 1.1 (0.2, >5)
Design | Followup duration | 0.5 (0.1, >5) | <0.1 (<0.1, 1.0) | 0.7 (0.1, >5) | 0.7 (0.1, >5) | 3.8 (0.3, >5)
Design | Randomization technique | 0.3 (<0.1, 2.2) | 0.2 (<0.1, 1.2) | 0.2 (<0.1, 1.0) | 0.4 (0.1, 2.8) | 0.7 (0.1, >5)
Design | Allocation concealment method | 3.6 (0.2, >5)^*^ | 0.5 (0.1, 2.0)^*^ | 3.6 (0.2, >5)^*^ | 0.3 (0.1, 1.3)^*^ | 0.5 (0.1, 2.0)^*^
Design | Intention-to-treat analysis | 1.3 (0.1, >5)^*^ | 0.2 (<0.1, 1.7)^*^ | 0.5 (<0.1, >5)^*^ | 0.1 (<0.1, 0.6)^*^ | 0.1 (<0.1, 0.4)^*^
Design | Power calculation | 0.3 (<0.1, 3.9) | <0.1 (<0.1, 0.7) | 0.4 (<0.1, >5) | >5 (<0.1, >5) | 0.6 (<0.1, >5)
Design | Subject blinding (explicit) | >5 (<0.1, >5) | 4.4 (0.2, 104.1) | 2.5 (0.1, >5) | 0.6 (<0.1, >5) | 0.3 (<0.1, 4.1)
Design | Caregiver blinding (explicit) | >5 (<0.1, >5) | 1.7 (0.2, >5) | 2.0 (0.2, >5) | 4.3 (0.2, >5) | 3.3 (0.2, >5)
Design | Outcome assessor blinding | 0.9 (0.2, >5) | 1.2 (0.3, >5) | 3.4 (0.4, >5) | 2.8 (0.3, >5) | 1.1 (0.2, >5)
Design | Double blinded | 2.4 (0.2, >5)^*^ | 0.1 (0.2, >5)^*^ | 0.5 (0.1, >5)^*^ | 2.4 (0.2, >5)^*^ | 1.0 (0.1, >5)^*^
Design | Single blinded | >5 (<0.1, >5)^*^ | 1.9 (<0.1, 4)^*^ | 1.2 (<0.1, >0.5)^*^ | 0.8 (<0.1, 1.3)^*^ | 0.6 (<0.1, >5)^*^
Design | Outcomes reported^†^ | 0.3 (0.1, 1.8) | 0.4 (0.1, 2.5) | <0.1 (<0.1, 0.5) | <0.1 (<0.1, 0.4) | 0.2 (<0.1, 1.0)
Design | No outcomes missed^‡^ | 1.3 (0.2, >5) | 0.9 (0.2, 4.7) | <0.1 (<0.1, 0.3) | <0.1 (<0.1, 0.4) | 0.1 (<0.1, 0.8)
Design | No extra outcomes added^**^ | 0.4 (<0.1, >5) | 0.2 (<0.1, 4.8) | 3.0 (0.1, 5) | 1.1 (<0.1, >5) | 4.1 (0.1, >5)
Intervention | Dose (of all interventions) | 1.6 (0.4, >5) | >5 (0.9, >5) | 0.8 (0.2, 2.8) | 2.1 (0.4, >5) | 0.9 (0.2, 4.2)
Intervention | Frequency (of all interventions) | 0.4 (<0.1, 4.0) | 1.0 (0.1, >5) | 0.9 (0.1, >5) | 0.4 (0.1, 3.8) | 0.7 (0.1, >5)
Intervention | Route (of all interventions) | <0.1 (<0.1, 2.9) | 0.3 (<0.1, >5) | 0.2 (<0.1, >5) | 0.5 (<0.1, >5) | >5 (<0.1, >5)
Intervention | Duration (of all interventions) | <0.1 (<0.1, 0.2) | 0.1 (<0.1, 0.9) | <0.1 (<0.1, 0.7) | 0.3 (<0.1, 2.3) | 0.1 (<0.1, 0.9)
Intervention | No. randomized (for all interventions) | >5 (1.1, >5) | 4.3 (0.6, >5) | >5 (1.1, >5) | 1.8 (0.3, >5) | 3.2 (0.5, >5)
Outcome | Description | 0.1 (<0.1, 0.8) | 0.2 (<0.1, 1.5) | 0.1 (<0.1, 1.0) | 0.5 (0.1, 2.8) | >5 (0.6, >5)
Results | No. analyzed (per intervention) | <0.1 (<0.1, 0.4) | <0.1 (<0.1, 0.9) | <0.1 (<0.1, 0.9) | <0.1 (<0.1, 0.3) | <0.1 (<0.1, 1.3)
Results | Mean or median reported^††^ | 2.8 (0.2, >5)^*^ | 2.3 (0.1, >5)^*^ | 0.4 (0.1, 1.6)^*^ | 0.2 (<0.1, 0.7)^*^ | 1.8 (0.1, >5)^*^
Results | Net difference^††^ | <0.1 (<0.1, 0.7) | <0.1 (<0.1, 0.4) | 0.6 (0.1, 3.7) | 0.5 (0.1, 3.6) | 0.3 (<0.1, 3.2)
Results | Standard error of net difference^††^ | 0.1 (<0.1, 0.9) | <0.1 (<0.1, 0.5) | 0.4 (0.1, 2.6) | 0.3 (<0.1, 2.3) | 0.6 (0.1, >5)
Results | No. events (counts) or odds ratio^‡‡^ | 0.8 (<0.1, >5) | <0.1 (<0.1, 1.9) | <0.1 (<0.1, 0.3) | <0.1 (<0.1, 0.5) | 0.2 (<0.1, >5)
Results | Reported P value of difference or odds ratio | <0.1 (<0.1, 0.2) | 0.3 (0.1, 2.0) | 0.2 (<0.1, 1.1) | <0.1 (<0.1, 0.2) | 0.2 (<0.1, 1.3)

Shading of cells matches reported percentages

Odds ratio (OR) ≥1 | 0.5<OR<1 (nonsignificant [NS]) | 0.1<OR≤0.5 (NS) | OR ≤ 0.1 (NS) | Statistically significant (OR<0.1).

* OR based on crude (unadjusted) proportions correct.

† From a list of proffered outcomes, there was exact agreement as to which were reported in the study.

‡ No outcomes found in the original article were missed from the translated article. This item is excluded from the overall percentages of items correct at the bottom of the table.

** No outcomes not found in the original article were added from the translated article. This item is excluded from the overall percentages of items correct at the bottom of the table.

†† For continuous outcomes.

‡‡ For dichotomous outcomes.

Risk of bias assessment typically had only slight agreement across languages and risk of bias questions. The median kappa across questions among the original language extractors (including for English articles) was 0.195 (full range -0.14, 0.78) and for extractors of translated articles was 0.22 (-0.46, 1.00). For English articles, 49 percent of biases were rated “unclear,” 12 percent “high,” and 39 percent “low.” Among other original language articles, 42 percent of biases were rated “unclear,” 18 percent “high,” and 39 percent “low.” Among translated articles, 53 percent of biases were rated “unclear,” 11 percent “high,” and 37 percent “low.” Table 9 displays the kappa values for each question, within each language, for both original and translated articles, along with P values for differences between original and translated extractions. Among 25 comparisons (5 questions in 5 languages), only 3 (12 percent) have a P value less than 0.10. Among Chinese and Spanish articles, allocation concealment was rated more consistently among translated than original articles (P = 0.06). This can be ascribed to the more universal designation of “unclear” bias among translated articles. Only for the designation of attrition bias among Chinese articles was agreement significantly poorer for translated articles (7 “unclear,” 1 “high,” 12 “low”) than for original articles (6 “unclear,” 3 “high,” 11 “low”).

Table 9 Kappa statistics for agreement of risk of bias

| | English | Chinese | French | German | Japanese | Spanish
Random'n Method | Orig | 0.37 (0.26, 0.48) | 0.67 (0.21, 1.00) | 0.33 (-0.07, 0.74) | 0.62 (0.04, 1.00) | 0.14 (-0.33, 0.61) | 0.01 (-0.30, 0.33)
Random'n Method | Trx | | 0.63 (0.08, 1.00) | 0.12 (-0.38, 0.61) | 0.22 (-0.32, 0.76) | -0.31 (-0.85, 0.24) | 0.39 (-0.23, 1.00)
Random'n Method | P | | 0.91 | 0.50 | 0.33 | 0.22 | 0.28
Allocation Conceal't Method | Orig | 0.28 (0.18, 0.38) | 0.26 (-0.18, 0.70) | -0.14 (-0.57, 0.29) | 0.78 (0.27, 1.00) | 0.02 (-0.06, 0.10) | 0.07 (-0.10, 0.24)
Allocation Conceal't Method | Trx | | 1.00 (0.38, 1.00) | -0.39 (-0.87, 0.10) | 0.38 (-0.16, 0.92) | 0.24 (-0.28, 0.76) | 1.00 (0.38, 1.00)
Allocation Conceal't Method | P | | 0.06 | 0.46 | 0.29 | 0.42 | <0.01
Patient Caregiver Blinding | Orig | 0.18 (0.10, 0.27) | 0.29 (-0.06, 0.63) | 0.11 (-0.05, 0.28) | -0.00 (-0.43, 0.43) | 0.26 (-0.12, 0.65) | 0.50 (0.04, 0.96)
Patient Caregiver Blinding | Trx | | 0.01 (-0.46, 0.48) | -0.08 (-0.55, 0.38) | 0.21 (-0.24, 0.66) | 0.07 (-0.37, 0.51) | 0.34 (-0.13, 0.81)
Patient Caregiver Blinding | P | | 0.35 | 0.44 | 0.51 | 0.51 | 0.63
Outcome Assessor Blinding | Orig | 0.28 (0.18, 0.37) | -0.11 (-0.55, 0.33) | 0.10 (-0.12, 0.33) | 0.29 (-0.05, 0.62) | -0.10 (-0.37, 0.18) | 0.13 (-0.24, 0.50)
Outcome Assessor Blinding | Trx | | -0.30 (-0.79, 0.18) | 0.03 (-0.43, 0.49) | 0.22 (-0.32, 0.76) | -0.46 (-0.93, 0.01) | 0.51 (0.04, 0.98)
Outcome Assessor Blinding | P | | 0.56 | 0.78 | 0.85 | 0.18 | 0.21
Attrition Bias | Orig | 0.04 (-0.05, 0.13) | 0.38 (0.04, 0.73) | 0.00 (-1.00, -1.00) | 0.21 (-0.18, 0.60) | 0.29 (-0.16, 0.73) | 0.05 (-0.15, 0.26)
Attrition Bias | Trx | | -0.36 (-0.90, 0.18) | 0.34 (-0.13, 0.81) | 0.55 (0.02, 1.00) | 0.45 (-0.10, 0.99) | 0.31 (-0.19, 0.81)
Attrition Bias | P | | 0.02 | * | 0.31 | 0.65 | 0.35

Formatting coding

κ<0 (poor agreement) | κ 0-0.20 (slight agreement) | κ 0.21-0.40 (fair agreement) | κ 0.41-0.60 (moderate agreement) | κ 0.61-0.80 (substantial agreement) | κ 0.81-1.00 (almost perfect agreement).

Bolded P values are those where P<0.10.

Conceal't = concealment, Orig = original language articles, P = P value (between original and translated articles), Random'n = randomization, Trx = translated articles.

* P value could not be estimated

We performed sensitivity analyses where we dichotomized the risk of bias assessment by setting “unclear” to be equivalent to either “high” or “low” risk of bias. The only finding that was different between the main and sensitivity analyses was when “unclear” was set to be equivalent to “high” risk of bias, among translated Spanish articles, outcome assessor blinding was more consistently graded “high/unclear” (75 percent) than among original articles (60 percent), P = 0.06.

## Association Between Extractor Confidence and Accuracy

Table 5 above displays the distribution of levels of confidence extractors had in the accuracy and completeness of the translations across languages. To examine the association between their level of confidence and their extraction accuracy, we first calculated the raw percentage accuracy by confidence level, by language and across languages (Table 10). For French articles the accuracy was considerably higher when extractors had strong confidence (94 percent accuracy across articles and items) than moderate or little confidence (67 percent accuracy). However, this pattern was not seen for other languages and of note, for Chinese articles the accuracy was higher when extractors had little confidence (88 percent) than moderate or strong accuracy (73 percent). Overall across all languages, the accuracy was about the same regardless of extractors' confidence level (76 or 79 percent).

Table 10 Association between extractors' confidence in accuracy of translation and their extraction accuracy

Confidence | Chinese, Percent Accurate | French,^*^ Percent Accurate | German, Percent Accurate | Japanese, Percent Accurate | Spanish, Percent Accurate | Overall,^*^ Percent Accurate
Strong | 73% | 94% | 78% | 66% | 80% | 79%
Moderate | 78% | 76% | 77% | 69% | 83% | 76%
Little | 88% | 67% | 74% | 75% | 74% | 76%

* 1 extractor did not rate confidence level for 1 article.