# References

1 Egger M, Zellweger-Zahner T, Schneider M, et al. Language bias in randomised controlled trials published in English and German. Lancet. 1997;350(9074):326-9. [pmid: 9251637].
2 Committee on Standards for Systematic Reviews of Comparative Effectiveness Research. Finding what works in health care: standards for systematic reviews. Washington, DC. 2011.
3 Heres S, Wagenpfeil S, Hamann J, et al. Language bias in neuroscience—is the Tower of Babel located in Germany?. Eur Psychiatry. 2004;19(4):230-2. [pmid: 15196606].
4 Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].
5 Gregoire G, Derderian F, Le LJ. Selecting the language of the publications included in a meta-analysis: is there a Tower of Babel bias?. J Clin Epidemiol. 1995;48(1):159-63. [pmid: 7853041].
6 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. 2002;31(1):115-23. [pmid: 11914306].
7 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. 2000;53(9):964-72. [pmid: 11004423].
8 Morrison A, Moulton K, Clark M, et al. English-language restriction when conducting systematic review-based meta-analyses: systematic review of published studies. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2009. http://cadth.ca/media/pdf/H0478_Language_Restriction_Systematic_Review_Pub_Studies_e.pdf. August 30, 2012.
9 Pham B, Klassen TP, Lawson ML, et al. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005;58(8):769-76. [pmid: 16086467].
10 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
11 Robinson KA, Dickersin K. Development of a highly sensitive search strategy for the retrieval of reports of controlled trials using PubMed. Int J Epidemiol. 2002;31(1):150-3. [pmid: 11914311].
12 Aiken M, Ghosh K, Wee J, et al. An evaluation of the accuracy of online translation systems. Communications of the IIMA (International Information Management Association). December. 2009. http://findarticles.com/p/articles/mi_7099/is_4_9/ai_n56337599/?tag=content. 11 Jul 2012.
13 Aiken M, Balan S. An analysis of Google Translate accuracy. Translation Journal. April. 2011;16(2). http://translationjournal.net/journal/56google.htm. 10 Jul 2012.
14 Freitas de Souza R, Sequeira P, Nasser M, et al. [P08-5] Is Google Translate useful for the selection of studies to be included in Cochrane reviews?. 17th Cochrane Colloquium. Singapore. 11-14 October 2009. http://www.imbi.unifreiburg.de/OJS/cca/index.php?journal=cca&page=article&op=view&path%5B%5D=8037 (http://www.imbi.uni-freiburg.de/OJS/cca/index.php?journal=cca&page=article&op=view&path%5B%5D=8037). 11 Jul 2012.
15 Balk EM, Chung M, Hadar N, et al. Accuracy of Data Extraction of Non-English Language Trials With Google Translate. Methods Research Report. (Prepared by the Tufts Evidence-based Practice Center under Contract No. 290-2007-10055 I.) AHRQ Publication No. 12-EHC056-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
16 Ip S, Hadar N, Keefe S, et al. A Web-based archive of systematic review data. Systematic Reviews. 2012;1:15. http://www.systematicreviewsjournal.com/content/1/1/15. [pmid: 22588052].
17 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. 1977;33(1):159-74. [pmid: 843571].