# Methods

An invitation was sent to all EPCs to join in the current methods project. The invitation requested that participating EPCs nominate investigators to extract original language articles, translated articles, or both. For extraction from original language articles, EPCs were asked to offer fluent speaking investigators from within their EPCs, from their regular cohort of collaborating investigators, or from other investigators who could subcontract with them.

Figure 1 displays a flowchart of the basic processes of the data extraction, reconciliation, and analysis.

Figure 1 Flowchart of basic processes

The figure displays a flowchart of the major steps involved in conducting the study. From left to right, 10 articles in 5 languages had double extraction by original language extractors; there was reconciliation of these articles, which created a reference standard. The same 10 articles in 5 languages were simultaneously translated in Google Translate and had double extraction by English extractors; these produced the extracted items. The extracted items and the reference standards were compared. In parallel, 10 articles in English had extraction by all English extractors; the extracted items were reconciled to produce reference standards; the extracted items were then compared to the reference standards; these English language extracted items served as controls for reviewer effects in the generalized linear mixed effects model of the comparison of translated extracted items to original language extracted items.

## Study Selection

Based on the frequency of non–English-language publications, a consensus on the most important languages to test, and the languages spoken by native speakers available to the collaborating EPCs, we included articles in the following five languages: Chinese, French, German, Japanese, and Spanish.

Using QUOSA Information Manager™ (v 8.07.265, QUOSA, Inc.) software, which allowed us to search in PubMed and automatically retrieve available PDF files, we searched with the term “randomized controlled trial,” restricted separately to each of the five languages. This tool can retrieve PDF files from all journals for which the Tufts University Health Services Library has a subscription or that are publicly available. We accepted the first 10 publications of trials in each language, regardless of topic, for which either a machine readable PDF or HTML file was available for the full text of the article. We did not use a publication date limitation, but in practice we included more recent publications (since we accepted the first 10 eligible articles and articles had to be available in PDF or HTML file formats). We accepted only studies with these file types since otherwise they could not be translated with Google Translate.

We estimated that we had resources for approximately 10 articles per language. We explored whether this would be sufficient to show statistical significance for differences between languages as large as those observed in the pilot study between the language with the worst agreement (50 percent among all items and extractors) and that with the best agreement (82 percent among all items and extractors).15 We simulated 500 datasets for 10 reviewers extracting 10 articles each, for 5 (non-English) languages, assuming that reviewers were completely exchangeable and allocated in a balanced way; that papers were indistinguishable given language; and that the true probability for correct extraction in the five languages was regularly spaced between 50 and 82 percent. We ran logistic regression models similar to the ones used in the final analysis, and focused on the omnibus P-value for language factors (which expresses the language effect). The observed power to detect differences was above 80 percent.

Full-text articles were screened by a researcher who was native in that language to determine eligibility. Eligible studies were randomized controlled trials that reported per-treatment group results data. We excluded publications that had a simultaneous English translation in the PDF or HTML file. We also excluded publications that were not primary reports of trials (but were summaries of English-language trials).

In addition, we chose 10 English-language randomized controlled trials to use as a reference standard. Also using the same search technique in QUOSA, we arbitrarily chose English-language articles that met criteria and were published in a distribution of years roughly corresponding to the distribution of the non-English articles.

## Translation

Each article was translated into English using Google Translate. This was done with the simplest method possible for each PDF (or HTML) file. Depending on the format of the articles, the English translations included the original tables and figures, translated the best they could be. We also copied over any English language abstracts that were published with the original articles, together with English language tables and figures. Each article was translated into a separate Word file that could be accessed without seeing the original article. Images of figures and tables that could not be translated due to formatting issues were included in the translated article files. The detailed methods for article translation are presented in the report of the pilot study.15 Translations were performed primarily by a research assistant. A rough estimate of the time required to extract each study was tracked.

## Data Extraction

All data extraction was performed in the data extraction tool, Systematic Review Data Repository (SRDR, Tufts Medical Center, Boston, Massachusetts), being developed at Tufts EPC.16 The tool allows creation of flexible data extraction forms, direct entry of extracted data, reconciliation, and export of extracted data in an online format. The tool maintained independence of extractions by restricting extractors' access to their own extractions (except for administrators who had access to all extraction forms). The extraction items are listed in Appendix A.

Each original language version of the articles was double extracted by two fluent readers of medical text in those languages. The double extractions were checked for agreement at Tufts EPC, who informed the pairs of extractors of items that required reconciliation. The pairs of extractors (who were generally in different time zones) communicated by email and/or telephone to come to agreement. The reconciled version of the extractions from the original language articles served as the reference standard for those articles.

The translated versions of the articles, which included the English language abstract when available, were extracted by eight researchers who did not speak the original language of the articles. Each translation was extracted by two researchers. Assignments were made arbitrarily (though not strictly randomly) with the goals of distributing extractors across languages, avoiding frequent pairing of researchers, and avoiding assigning translated articles to researchers who could read the original language of the articles. These researchers also extracted the 10 English-language articles (to serve as a control for “reviewer effects”; see Analysis below). Reconciliation of the extractions of English language articles was conducted by consensus either of five of eight extractors or, failing that, agreement between the two senior researchers at Tufts EPC.

### Data Extraction Form

Since we were primarily interested in the accuracy of the data extraction, as opposed to the accuracy of all the text, we performed limited data extraction focusing on those study features that are most important for assessing the study characteristics, methods, and results (see Appendix A for the data extraction items).

We extracted the following information: inclusion and exclusion criteria; funding source; number of study centers; followup duration; whether the article reported randomization technique, allocation concealment method, intention-to-treat analyses, a power calculation; blinding (subjects, caregivers, outcome assessors, double blinding, single blinding); outcomes reported (see last paragraph in this section); interventions and controls, and their dose, frequency, route, and duration; numbers randomized to each intervention; and outcome descriptions. For a single (preselected) continuous outcome, we extracted the number of subjects analyzed per intervention, whether mean or median data were reported, the net difference (or difference between final values, depending on reported data), its standard error, the reported P value for the difference between groups, and what, if any, factors were adjusted for. For a single (preselected) categorical (dichotomous) outcome, we extracted the number of events (counts) and number analyzed per intervention, the odds ratio with its 95 percent confidence interval, the reported P value for the difference between groups, and what, if any, factors were adjusted for. We provided extractors with a standardized calculator in Excel for use when between-group comparison data were not reported but needed to be calculated (e.g., for odds ratio). In addition, we also asked extractors of translated articles two subjective, best guess questions: to provide a rough estimation of how much extra time they believe they spent with the article compared to an extraction of a similar English article (<5 minutes extra time, 6 to 30 minutes extra time, or >30 minutes extra time), their level of confidence in the accuracy and translation of the article (little confidence, moderate confidence, or strong confidence). Extractors were also asked for examples of poor translations that made extraction difficult.

Upon analyzing the extracted data, the following items were removed from analysis: whether analyses were adjusted and what the analyses were adjusted for (extremely few articles had adjusted analyses extracted); and calculated odds ratio (which was not consistently calculated correctly and was redundant with the counts and numbers analyzed).

Whenever possible, we selected one categorical outcome and one continuous outcome from each trial. Ideally, one of the two outcomes was presented in the abstract (and the full text) and one was presented in full text only. When necessary, we limited the extraction of results to two of multiple interventions, with a preference for the intervention most similar to a “control” and another arbitrary intervention. Also when necessary, a single timepoint was arbitrarily chosen, with a preference for longer followup periods.

Prior to data extraction, for each language we compiled a list of about a dozen outcomes that were reported in at least one article in that language. This was done with the assistance of native speakers. We aimed for a mix of primary and secondary outcomes, and clinical and intermediate (or surrogate) outcomes. During data extraction, researchers were asked to review the list of outcomes and check off all outcomes that were reported in the article. This item was added with the goal of determining the accuracy of finding potential outcomes of interest in translated articles (which would determine whether a study is included for a particular outcome).

### Data Extraction Comparison

Reconciliation of the original language extractions (including English) and then comparisons of translations with the reconciled original language extractions were conducted either within SRDR or with data exported into Excel. For the comparisons of translations (and of English extractions) with their reference standards, each data item was coded as agree or disagree. “Disagree” included erroneous data, incomplete data (e.g., descriptions of eligibility criteria, lists of outcomes reported), and data items incorrectly extracted as not reported (no data).

For numerical data and for questions that allowed checkboxes or pulldown menus, comparisons were simple and objective. However, several questions involved text responses that required subjective assessment to determine agreement, including inclusion criteria, exclusion criteria, and descriptions of many interventions that were not drugs and required more qualitative descriptions and did not have a “dose,” “frequency,” or “route.” For calculated numerical data, we were liberal in determining agreement, accepting mean differences, standard errors, odds ratios, and confidence intervals that were similar as being in agreement. We did this to minimize counting calculation differences as disagreements due to translation. During reconciliation of the English article extractions we found that for numerous articles there were reasonable differences in interpretation that resulted in different data being extracted. For example, vague wording led to different interpretations as to how many participants were analyzed or whether the reported P value was the P-value of the difference between interventions that we were interested in. Another common example was how to handle descriptions of interventions (e.g., how to handle the dose of a topical application where as much is used as is needed [no data vs. the concentration of the lidocaine in the application], the dose of therapy sessions [30-minute sessions vs. no data]). Since we could not adequately evaluate for all extractions of all articles whether differences were due to different interpretations or errors, we changed our approach to reconciliation. Where there were discrepancies between the double data extractors (from the original language articles) we asked the extractors to recheck and confirm their answers. If discrepancies remained after data checking, then both answers were accepted as correct answers. If the translated article extractor extracted either of the “correct” answers, this was treated as an agreement.

### Analysis

All 8 reviewers each extracted all 10 English-language papers, which served as a “common reference” in the analysis. Each translated non–English-language paper was extracted by two of the eight reviewers. It was not possible to allocate reviewers to non–English-language papers in a balanced way, because some reviewers were fluent in some non-English languages and for logistic reasons.

For each item, we used a generalized linear mixed effects model to examine whether the probability of correctly extracting the item is related to the language of the original publication and to the reviewer (extractor), accounting for the fact that reviewer extractions are grouped by paper. The model used the pattern of allocation of reviewers to languages to control for reviewer effects, and is a logistic regression with fixed slope and random intercept terms. Specifically, the logit-transformed probability of correctly extracting an item from paper i written in original language l is modeled as a linear function:

logit(P_correct_)=α_0_ + Σ_r=2…8_ β_r_I(reviewer=r) + Σ_r=2…6_ γ_r_I(language=l) +ζ_li_,

where α_0_ is an intercept, I( ) is the indicator function, r=1,…,8 indexes reviewers, l=1,…,6 indexes original languages, and ζ_li_ are paper-specific random intercepts normally distributed around 0. Reviewer 1 and language 1 (English) are the reference indicators. In the model, the βs are log odds ratios corresponding to reviewer effects. Similarly, the γs are the log odds ratios corresponding to language effects. The αs are random intercepts.

For each item, we report odds ratios for correct extraction for papers originally published in languages other than English compared with English-language papers. We use the fitted model to derive the predicted probability of correct classification for a hypothetical reviewer who is in some sense an average of the eight reviewers who extracted translated data. For some items virtually all extractions were correct, and the above model (and its fixed effects version) did not converge (perfect prediction). In these cases we ignored reviewer effects and calculated “crude” odds ratios for languages, and crude predicted probabilities of correct classification per language.

Separate from the main analyses, we used kappa statistics to quantify between-rater agreement in classifying five items on study risk of bias (methodological quality): randomization method, allocation concealment method, patient and caregiver blinding, outcome assessor blinding, and attrition rate (see Appendix A). We compared the kappa for agreement among the reviewers who extracted information from the original papers, with the kappa for agreement among reviewers who used the translated papers. We performed sensitivity analyses by merging “unclear” with “low” and “unclear” with “high” risk of bias. We used the Landis and Koch interpretation of values of kappa to determine the level of agreement.17

κ | Interpretation
<0 | Poor agreement
0–0.20 | Slight agreement
0.21–0.40 | Fair agreement
0.41–0.60 | Moderate agreement
0.61–0.80 | Substantial agreement
0.81–1.00 | Almost perfect agreement