# Acknowledgments

We would like to thank and acknowledge the following investigators for their insights into the study design and methods and/or for their data extractions: Sophia Tsouros, B.H.Kin, University of Ottawa Evidence-based Practice Center; Mohammed T. Ansari, M.B.B.S., M.Med.Sc., M.Phil., University of Ottawa Evidence-based Practice Center; Jordi Pardo Pardo, University of Ottawa, Centre for Global Health; Sydne J. Newberry, Ph.D., Southern California Evidence-based Practice Center; Susanne Hempel, Ph.D., Southern California Evidence-based Practice Center; Melisa Chang, M.D., Southern California Evidence-based Practice Center; Paul G. Shekelle, M.D., Ph.D., Southern California Evidence-based Practice Center; Joann Fontanarosa, Ph.D., ECRI Institute Evidence-based Practice Center; Fang Sun, M.D., Ph.D., ECRI Institute Evidence-based Practice Center; Katrin Uhlig, M.D., M.S., Tufts Evidence-based Practice Center; Teruhiko Terasawa, M.D., Ph.D., Fujita Health University, School of Medicine, Tsu, Japan; Nikolaos A. Trikalinos, M.D., University of Maryland, Marlene and Stewart Greenebaum Cancer Center, Baltimore, MD; Fumiaki Imamura, Ph.D., Harvard School of Public Health, Boston, MA; and Issa J. Dahabreh, M.D. M.S., Tufts Evidence-based Practice Center. Boston, MA.