# List of Translated and Included Articles

## Chinese

Hu XY, Zhou YX, Xu SZ, Lin YY. Effects of probiotics on feeding intolerance in low birth weight premature infants. [Chinese]. Zhongguo Dang Dai Er Ke Za Zhi. 2010;12:693-5. [pmid: 20849715].
Li H, Dong L, Li Y, Fu S. A randomized clinical trial of combination of Aidi injection with Gemcitabine and Oxaliplatin regimen or Go regimen only in the treatment of advanced non-small-cell lung cancer. [Chinese]. Zhongguo Fei Ai Za Zhi. 2008;11:570-3. [pmid: 20735973].
Liu X, Liu D, Li J, Ou D, Zhou Z. Safety and efficacy of carbon dioxide insufflation during colonoscopy. [Chinese]. Zhong Nan Da Xue Xue Bao Yi Xue Ban. 2009;34:825-9. [pmid: 19734597].
Tang FZ, Liu YL, Wen FQ, Zhang ZX. Comparison of therapeutic effects in severe nocturia: gradual versus immediate drug withdrawal. [Chinese]. Zhongguo Dang Dai Er Ke Za Zhi. 2010;12:198-200. [pmid: 20350430].
Wang P, Yang J, Liu G, Chen H, Yang F. Effects of moxibustion at head-points on levels of somatostatin and arginine vasopressin from cerebrospinal fluid in patients with vascular dementia: a randomized controlled trial. [Chinese]. Zhong Xi Yi Jie He Xue Bao. 2010;8:636-640. [pmid: 20619139].
Xu JS, Yang JW, Gu MN, Chen YM. Effects of fentanyl on EC50 of ropivacaine for postoperative epidural analgesia after gynecological surgery. [Chinese]. Di Yi Jun Yi Da Xue Xue Bao. 2004;24:1326-7. [pmid: 15567796].
Xu XH, Chang YT, Li L, Li J, Zhang DM, Zou XH. Effect of fructose-1,6-diphosphete on myocardial preservation during pulmonary operations. [Chinese]. Zhong Nan Da Xue Xue Bao Yi Xue Ban. 2008;33:966-9. [pmid: 19001742].
Yang MH, Li M, Dou YQ, et al. Effects of Bushen Huoxue Granule on motor function in patients with Parkinson's disease: a multicenter, randomized, double-blind and placebo-controlled trial. [Chinese]. Zhong Xi Yi Jie He Xue Bao. 2010;8:231-7. [pmid: 20226144].
Yi JH, Li RR. Influence of near-work and outdoor activities on myopia progression in school children. [Chinese]. Zhongguo Dang Dai Er Ke Za Zhi. 2011;13:32-5. [pmid: 21251384].
Zhang GQ, Ge L, Ding W, Li HJ. The value of portal vein chemotherapy after radical resection in delaying intrahepatic recurrence of stage II primary hepatocellular carcinoma. [Chinese]. Ai Zheng. 2008;27:1297-301. [pmid: 19079997].

## French

Aubin M, Vezina L, Maziade J, Robitaille NM. Control of arterial hypertension: effectiveness of an intervention performed by family practitioners. [French]. Can Fam Physician. 1994;40:1742-52. [pmid: 7950469].
Aydin A, Karadayi K, Aykan U, Can G, Colakoglu K, Bilge AH. Effectiveness of topical ciclosporin A treatment after excision of primary pterygium and limbal conjunctival autograft. [French]. J Fr Ophtalmol. 2008;31:699-704. [pmid: 18971855].
Baillargeon L, Drouin J, Desjardins L, Leroux D, Audet D. The effects of Arnica Montana on blood coagulation. Randomized controlled trial. [French]. Can Fam Physician. 1993;39:2362-7. [pmid: 7903572].
Devogelaere T, Beresniak A, Raymaeckers A, Naacke H, Ssi YK I, Bremond-Gignac D. Clinical study of Supranettes pads in the treatment of seasonal or perennial allergic conjunctivitis in children. [French]. J Fr Ophtalmol. 2006;29:593-8. [pmid: 16885888].
Fekih M, Ben ZN, Jnifen A, et al. Comparing two Prepidil gel regimens for cervical ripening before induction of labor at term: a randomized trial. [French]. J Gynecol Obstet Biol Reprod (Paris). 2009;38:335-40. [pmid: 19467806].
Gadioux-Madern F, Lelez ML, Sellami L, et al. Influence of the instillation of two versus three eyedrops of cyclopentolate 0.5% on refraction of Caucasian nonstrabismic children. [French]. J Fr Ophtalmol. 2008;31:51-5. [pmid: 18401299].
Gosselin P, Verreault R, Gaudreault C, Guillemette J. Dietary treatment of mild to moderate hypercholesterolemia. Effectiveness of different interventions. [French]. Can Fam Physician. 1996;42:2160-7. [pmid: 8974552].
Lamouliatte H, Perie F, Joubert-Collin M. Treatment of Helicobacter pylori infection with lansoprazole 30 mg or 60 mg combined with two antibiotics for duodenal ulcers. [French]. Gastroenterol Clin Biol. 2000;24:495-500. [pmid: 10891736].
Polonovski JM, El MM. Treatment of acute maxillary sinusitis in adults. Comparison of cefpodoxime-proxetil and amoxicillin-clavulanic acid. [French]. Presse Med. 2006;35:33-8. [pmid: 16462661].
Rolachon A, Kezachian G, Causse X, et al. Value of high-dose interferon-alpha in chronic viral hepatitis C patients non-responder to a 1st treatment. Pilot study prospective and randomized trial. [French]. Gastroenterol Clin Biol. 1997;21:924-8. [pmid: 9587555].

## German

Bechdolf A, Pohlmann B, Guttgemanns J, et al. State-dependent motivational interviewing for people with schizophrenia and substance use : Results of a randomised controlled trial. [German]. Nervenarzt. 2012;83:888-96. [pmid: 21720841].
Birnbaum F, Schwartzkopff J, Bohringer D, Reinhard T. Penetrating keratoplasty with intrastromal corneal ring. A prospective randomized study. [German]. Ophthalmologe. 2008;105:452-6. [pmid: 17899113].
Borner M, Burkle H, Trojan S, Horoshun G, Riewendt HD, Wappler F. Intra-articular ketamine after arthroscopic knee surgery. Optimisation of postoperative analgesia. [German]. Anaesthesist. 2007;56:1120-7. [pmid: 17726586].
Langer C, Forster H, Konietschke F, et al. Mesh shrinkage in hernia surgery: data from a prospective randomized double-blinded clinical study. [German]. Chirurg. 2010;81:735. [pmid: 20186380].
Marx S, Cimniak U, Beckert R, Schwerla F, Resch KL. Chronic prostatitis/chronic pelvic pain syndrome. Influence of osteopathic treatment - a randomized controlled study. [German]. Urologe A. 2009;48:1339-45. [pmid: 19705093].
Meybohm P, Hanss R, Bein B, et al. Comparison of premedication regimes. A randomized, controlled trial. [German]. Anaesthesist. 2007;56:890-6. [pmid: 17551699].
Schnabel M, Vassiliou T, Schmidt T, et al. Results of early mobilisation of acute whiplash injuries. [German]. Schmerz. 2002;16:15-21. [pmid: 11845337].
Stoffels I, Wolter TP, Sailer AM, Pallua N. The impact of silicone spray on scar formation. A single-center placebo-controlled double-blind trial. [German]. Hautarzt. 2010;61:332-8. [pmid: 19967328].
Warlo I, Krummenauer F, Dick HB. Rotational stability in intraocular lenses with C-loop haptics versus Z haptics in cataract surgery. A prospective randomised comparison. [German]. Ophthalmologe. 2005;102:987-92. [pmid: 15785909].
Wohlrab D, Droege JW, Mendel T, et al. Minimally invasive vs. transgluteal total hip replacement. A 3-month follow-up of a prospective randomized clinical study. [German]. Orthopade. 2008;37:1121-6. [pmid: 18810386].

## Japanese

Adachi Y, Sumikuma T, Kagami R, et al. Improvement of patient adherence by mixing oral itraconazole solution with a beverage (orange juice). [Japanese]. Rinsho Ketsueki. 2010;51:315-9. [pmid: 20534951].
Hirata K, Nakahara S, Shimokobe T, et al. A randomized controlled trial of postoperative adjuvant chemotherapy for colorectal cancer-optimal duration of the treatment. [Japanese]. Gan To Kagaku Ryoho. 2009;36:77-82. [pmid: 19151567].
Kurokawa M, Masuda Y, Noda M, et al. Minimal effective dose on serum cholesterol concentration and the safety evaluation of dressing containing plant sterol in Japanese subjects. [Japanese]. J Oleo Sci. 2008;57:23-33. [pmid: 18075220].
Miura H, Takahashi Y, Kitabatake Y. Influence of group training on pulse wave velocity in elderly women. [Japanese]. Nihon Koshu Eisei Zasshi. 2010;57:271-8. [pmid: 20560409].
Mochizuki M, Hatsugaya M, Rokujoh E, et al. Randomized controlled study on the effectiveness of community pharmacists' advice for smoking cessation by Nicorette--evaluation at three months after initiation. [Japanese]. Yakugaku Zasshi. 2004;124:989-95. [pmid: 15577269].
Satou Y, Kanda J, Okumura M, Nishida K. An analysis of the educational effects of group counseling with visual aids: efforts to prevent diabetes in a business office setting. [Japanese]. Sangyo Eiseigaku Zasshi. 2004;46:117-21. [pmid: 15382712].
Sawada A, Sakata N, Higuchi B, et al. Comparison of micafungin and fosfluconazole as prophylaxis for invasive fungal infection during neutropenia in children undergoing chemotherapy and hematopoietic stem cell transplantation. [Japanese]. Rinsho Ketsueki. 2009;50:1692-9. [pmid: 20068276].
Sekine Y, Takai Y, Nishii O, et al. Establishment of an optimum bowel preparation method before gynecologic laparoscopic surgery. [Japanese]. Yakugaku Zasshi. 2001;121:637-45. [pmid: 11523124].
Sugiura M, Hata Y, Fukuda T, et al. One-week application of terbinafine cream compared with four-week application in treatment of Tinea pedis. [Japanese]. Nihon Ishinkin Gakkai Zasshi. 2001;42:223-8. [pmid: 11704752].
Takahashi M, Araki A, Ito H. Development of a new method for simple dietary education in elderly individuals with diabetes mellitus. [Japanese]. Nihon Ronen Igakkai Zasshi. 2002;39:527-32. [pmid: 12404749].

## Spanish

Bonetto G, Salvatico E, Varela N, Cometto C, Gomez PF, Calvo B. Pain prevention in term neonates: randomized trial for three methods. [Spanish]. Arch Argent Pediatr. 2008;106:392-6. [pmid: 19030637].
Ceriani Cernadas JM, Carroli G, Pellegrini L, et al. The effect of early and delayed umbilical cord clamping on ferritin levels in term infants at six months of life: a randomized, controlled trial. [Spanish]. Arch Argent Pediatr. 2010;108:201-8. [pmid: 20544134].
de Luis DA, de la FB, Izaola O, et al. Randomized clinical trial with a inulin enriched cookie on risk cardiovascular factor in obese patients. [Spanish]. Nutr Hosp. 2010;25:53-9. [pmid: 20204256].
Garcia-Talavera Espin NV, Gomez Sanchez MB, Zomeno Ros AI, et al. Comparative study of two enteral feeding formulas in hospitalized elders: casein versus soybean protein. [Spanish]. Nutr Hosp. 2010;25:606-12. [pmid: 20694297].
Gomez-Garcia A, Hernandez-Salazar E, Gonzalez-Ortiz M, Martinez-Abundis E. Effect of oral zinc administration on insulin sensitivity, leptin and androgens in obese males. [Spanish]. Rev Med Chil. 2006;134:279-84. [pmid: 16676098].
Lopez-De-Blanc SA, Salati-De-Mugnolo N, Femopase FL, et al. Antifungal topical therapy in oral chronic candidosis. A comparative study. Med Oral. 2002;7:260-70. [pmid: 12134127].
Martinez Gonzalez JM, Benito PB, Fernandez CF, San Hipolito ML, Penarrocha DM. A comparative study of direct mandibular nerve block and the Akinosi technique. Med Oral. 2003;8:143-9. [pmid: 12618675].
Perez-Barcena J, Barcelo B, Homar J, et al. Comparison of the effectiveness of pentobarbital and thiopental in patients with refractory intracranial hypertension. Preliminary report of 20 patients. [Spanish]. Neurocirugia (Astur ). 2005;16:5-12. [pmid: 15756405].
Rodriguez MC, Castano SC, Garcia OL, Recio Rodriguez JI, Castano SY, Gomez Marcos MA. Efficacy of an educational intervention group on changes in lifestyles in hypertensive patients in primary care: a randomized clinical trial. [Spanish]. Rev Esp Salud Publica. 2009;83:441-52. [pmid: 19701575].
Vasquez AM, Sanin F, Alvarez LG, Tobon A, Rios A, Blair S. Therapeutic efficacy of a regimen of artesunate-mefloquine-primaquine treatment for Plasmodium falciparum malaria and treatment effects on gametocytic development. [Spanish]. Biomedica. 2009;29:307-19. [pmid: 20128355].

## English

Davidson JA, Einhorn D, Allweiss P, et al. Effect of premixed nph and regular insulin on glucose control and health-related quality of life in patients with type 2 diabetes mellitus. Endocr Pract. 1997;3:331-6. [pmid: 15251769].
Friedman Z, Katznelson R, Phillips SR, et al. A randomized double-blind comparison of a morphine-fentanyl combination vs. morphine alone for patient-controlled analgesia following bowel surgery. Pain Pract. 2008;8:248-52. [pmid: 18503621].
Fu S, Choy NL, Nitz J. Controlling balance decline across the menopause using a balance-strategy training program: a randomized, controlled trial. Climacteric. 2009;12:165-76. [pmid: 19058060].
Halkes PH, van GJ, Kappelle LJ, Koudstaal PJ, Algra A. Medium intensity oral anticoagulants versus aspirin after cerebral ischaemia of arterial origin (ESPRIT): a randomised controlled trial. Lancet Neurol. 2007;6:115-24. [pmid: 17239798].
Ize-Iyamu IN, Saheeb BD. Feeding intervention in cleft lip and palate babies: a practical approach to feeding efficiency and weight gain. Int J Oral Maxillofac Surg. 2011;40:916-9. [pmid: 21641186].
Lyytinen J, Kaakkola S, Gordin A, Kultalahti ER, Teravainen H, Sovijarvi A. The effect of COMT inhibition with entacapone on cardiorespiratory responses to exercise in patients with Parkinson's disease. Parkinsonism Relat Disord. 2002;8:349-55. [pmid: 15177064].
Malpuech-Brugere C, Mouriot J, Boue-Vaysse C, et al. Differential impact of milk fatty acid profiles on cardiovascular risk biomarkers in healthy men and women. Eur J Clin Nutr. 2010;64:752-9. [pmid: 20485306].
Odergren A, Algvere PV, Seregard S, Libert C, Kvanta A. Vision-related function after low-dose transpupillary thermotherapy versus photodynamic therapy for neovascular age-related macular degeneration. Acta Ophthalmol. 2010;88:426-30. [pmid: 20597872].
Solon FS, Sarol JN Jr, Bernardo AB, et al. Effect of a multiple-micronutrient-fortified fruit powder beverage on the nutrition status, physical fitness, and cognitive performance of schoolchildren in the Philippines. Food Nutr Bull. 2003;24:S129-S40. [pmid: 17016955].
Wang WC, Morales KH, Scher CD, et al. Effect of long-term transfusion on growth in children with sickle cell anemia: results of the STOP trial. J Pediatr. 2005;147:244-7. [pmid: 16126058].