# Results

## Assemble an Interdisciplinary Panel of Experts

We recruited a panel of experts in the development and implementation of interventions, methods experts, and policymakers. We sought to include stakeholders who worked in different parts of the world, who developed or studied different types of global health problems, and who were expert in different types of evaluation methods. The members of the TEP are listed in the front matter.

## Select a Set of “Exemplar Interventions or Programs”

From suggestions by experts and the literature, we selected a number of global health interventions or programs as candidates for our exemplars. We then categorized each of these using the dimensions we had developed (see Appendix A). We sent this information to our TEP and asked for the comments and input on which exemplars to choose. From this process we chose two exemplars that were on our original list—household water chlorination and interventions to prevent mother to child transmission (PMTCT) of HIV, and a third exemplar suggested by our TEP—the use of lay or community health workers (CHW) to improve maternal and child outcomes. This latter exemplar was specifically chosen since the use of chlorine to disinfect water and the use of antiretrovirals to reduce the transmission of HIV both have a “basic science” foundation. CHW is an example of intervention where this is not the case. Table 1 displays how we classified each exemplar according to our domains of diversity.

Table 1 Diversity of exemplar interventions across key criteria

Dimension/Examples | PMTCT | Household Water Chlorination | CHW
Populations affected by a disease – maternal health, adults, elderly, children | pregnant women | primarily children under 5 (diarrhea) | all, primarily children under 5
Populations affected by a disease – Africa vs. Asia vs. Latin America | Sub-Saharan Africa, Southeast Asia | all | all, primarily children under 5
Communicable vs. non-communicable disease | communicable | communicable | both
One time vs. continuous behavior | time limited | continuous | depends
Preventive or treatment | preventive | preventive | preventive and treatment
Delivery source for intervention | often publicly provided by NGOs | could be either | generally publicly provided by health system
Resource dimension | high | low | unknown
Individual vs. Community - level of impact | mostly individual | both | mostly individual
Individual vs. Community - level of intervention | individual | individual | community
Urban vs. Rural | urban and rural | urban and rural | mostly rural?

## Focused Literature Review on the Three Chosen Global Health Exemplar Interventions

We identified the following systematic reviews and original research studies for each intervention:

### Household Water Chlorination

The evidence base for household water chlorination stemmed from two 2007 systematic reviews of randomized and nonrandomized studies; one review4 was specific to household chlorine use, and the other5 assessed numerous water quality interventions and for these we isolated the chlorination studies where possible. Both reviews broadly searched numerous databases including Medline, Embase, LILACS and Cochrane. The review specifically about household chlorine use did not restrict based on study design, while the other reviews included only RCTs and quasi-randomized controlled trials. Three RCTs were included in both analyses. Meta-analyses of beneficial outcomes included 10 and 5 studies of chlorine, respectively. We applied the evidence frameworks to outcomes of both water quality and diarrheal morbidity as both were considered in the systematic reviews and due to the self-reported nature of diarrheal episodes in these studies. The pooled analysis in the review specific to household chlorine use found a .71 relative risk of child diarrhea outcomes (95% confidence interval [CI]: 0.58–0.87) and a 0.20 relative risk of water contamination outcomes (95% CI: 0.13–0.30) due to the interventions. Implementation data came from review of three of the original studies included in these reviews.6-8 Studies came from urban and rural settings within South America, Africa, Southeast and Central Asia.

### PMTCT

The primary piece of evidence on PMTCT was a high-quality Cochrane systematic review updated in 2011.^9^ The review focused on efficacy and safety of various antiretroviral regimens in low income countries; the primary outcome was percent of infants HIV positive at various time points postpartum. The review included only RCTs; there were 25 including almost 19,000 participants total. The review reports on the efficacy of various regimens in breast-feeding and non breast-feeding mothers and concludes that triple antiretroviral therapy is the most effective regimen. All antiretroviral interventions were found safe in the short term.

This review was complemented by a 2011 systematic review on cost-effectiveness of PMTCT in low and middle income countries.10 Nineteen peer-reviewed cost-effectiveness studies were included; 15 focused on antiretrovirals (ARV), while others included primary prevention of HIV, HIV testing strategies, prevention of unwanted pregnancies, and replacing of breast-feeding with other means. All articles conducted modeling with hypothetical cohorts; ARV regimens and their efficacy rates were often taken from the same trials included in the Cochrane review.9 Sixteen of the 19 studies concluded that PMTCT is cost-effective. Two others involved HIV testing in low prevalence areas and one other was conducted when the cost of antiretrovirals was significantly higher than in recent times.

The third review included only studies of ARV conducted in sub-Saharan Africa.11 It was limited to peer-reviewed RCTs; meta-analysis of 10 resulted in an estimate of about 50 percent efficacy in reducing HIV transmission from mother to child.

### Lay or Community Health Workers

For lay workers we identified a Cochrane Review on “lay health workers in primary and community health care for maternal and child health and the management of infectious diseases” that was updated as of October 2009.^12^ This review searched Medline, Embase, CINAHL, Cochrane and a number of other databases through early 2009. Eligible studies had to be RCTs. A “lay health worker” was defined as “any health worker carrying out functions related to health care delivery, trained in some way in the context of the intervention, and having no formal or professional or paraprofessional certificate or tertiary education degree.” A large number of different studies and outcomes were included in this review (82 studies and 25 different outcomes; of course most studies only assessed a limited number of outcomes). Assessed outcomes included uptake of immunizations, promoting breastfeeding, mortality/morbidity among children less than 5 years of age, neonatal mortality, reported illnesses in children, care-seeking behavior, and various tuberculosis outcomes. From these we chose the outcome “reduce morbidity in children under 5 years of age” as it seemed to be both an outcome very important to communities and it had enough studies to make a meta-analysis meaningful (3 trials). Seven trials were included, which were conducted in Bangladesh (2 studies), Thailand, Burkina Faso, India, Nepal, and Vietnam. The pooled analysis of all 7 studies was a reduction in reported illness in children of 0.86 (95% CI 0.75, 0.99). The conclusion of the review was that the use of lay health workers, compared with usual care “may lead to slightly fewer children who suffer from fever, diarrhea and pneumonia.”

### Assessment of Strengths and Limitations of Existing Frameworks For Assessing Global Health Interventions

In our efforts to identify frameworks, we reviewed more than 50 documents identified by our search methods described earlier. Many contained helpful suggestions of areas to focus on when assessing public health interventions in low and middle income countries. However, only six included clear criteria with a rating system and instructions for application to a body of evidence on an intervention. Most of these frameworks had some areas of overlap, such as greater weight given to evidence generated by randomized controlled trials. However, the relative weight given to other study designs, as well as the consideration of factors such as details of implementation and the generalizability of findings received differing amounts of consideration across the frameworks. We briefly summarize main points of these six frameworks in Table 2.

Table 2 Public health/global health frameworks

Framework Name | Grades Assigned | Domains for Grading Evidence | Notes on Domains
Tang, Choi, Beaglehole Journal of Epidemiology of Community Health 2008^13^(Drawn from Tang et al.'s Table 1 for grading of evidence on association, repeatability and causal mechanism) | Grades of 1 (strong), 2 (weak), and 3 (insufficient). Expanded categories include grade 2A (probable), 2B (possible) and 2C (limited). | Association | “High” association is defined as a RR of greater than 2. Otherwise “low” or “none.”
Tang, Choi, Beaglehole Journal of Epidemiology of Community Health 2008^13^(Drawn from Tang et al.'s Table 1 for grading of evidence on association, repeatability and causal mechanism) | Grades of 1 (strong), 2 (weak), and 3 (insufficient). Expanded categories include grade 2A (probable), 2B (possible) and 2C (limited). | Repeatability | Wide or Limited
Tang, Choi, Beaglehole Journal of Epidemiology of Community Health 2008^13^(Drawn from Tang et al.'s Table 1 for grading of evidence on association, repeatability and causal mechanism) | Grades of 1 (strong), 2 (weak), and 3 (insufficient). Expanded categories include grade 2A (probable), 2B (possible) and 2C (limited). | How it works | How it works is known or not known
Grading of Recommendations Assessment, Development and Evaluation (GRADE)14 (Summarized from BMJ article Table 1.) | Four grades assigned: high, moderate, low, and very low quality of evidence. For “high” quality studies, definition is “We are very confident that the true effect lies close to that of the estimate of the effect.” | Randomized trials start with a “high” initial quality grade, observational studies start with a “low” grade. | Grades can be moved down depending on factors such as risk of bias or inconsistency, or up in light of a large measured effect or evidence of a dose-response.
Highest Attainable STandard of Evidence (HASTE)15 | Four grades assigned: Strong (Grade 1), Conditional (Grade 2), Insufficient (Grade 3), and Inappropriate (Grade 4). Conditional (Grade 2) has subcategories of Probable, Possible and Pending. | Efficacy | Whether consistent, limited or inconsistent
Highest Attainable STandard of Evidence (HASTE)15 | Four grades assigned: Strong (Grade 1), Conditional (Grade 2), Insufficient (Grade 3), and Inappropriate (Grade 4). Conditional (Grade 2) has subcategories of Probable, Possible and Pending. | Biological plausibility | Whether consistent, limited or inconsistent
Highest Attainable STandard of Evidence (HASTE)15 | Four grades assigned: Strong (Grade 1), Conditional (Grade 2), Insufficient (Grade 3), and Inappropriate (Grade 4). Conditional (Grade 2) has subcategories of Probable, Possible and Pending. | Implementation data availability | Whether available or not
U.S. Community Preventive Services Task Force (USCPSTF), Briss, Saza, Pappaioanou et al. 2000^16^ | Evidence is characterized as strong, sufficient or insufficient | Execution | Good or Fair
U.S. Community Preventive Services Task Force (USCPSTF), Briss, Saza, Pappaioanou et al. 2000^16^ | Evidence is characterized as strong, sufficient or insufficient | Design suitability | Greatest (RCTs), Moderate (no concurrent comparison group) or Least
U.S. Community Preventive Services Task Force (USCPSTF), Briss, Saza, Pappaioanou et al. 2000^16^ | Evidence is characterized as strong, sufficient or insufficient | Number of studies
U.S. Community Preventive Services Task Force (USCPSTF), Briss, Saza, Pappaioanou et al. 2000^16^ | Evidence is characterized as strong, sufficient or insufficient | Consistent | “Generally consistent in direction and size”
U.S. Community Preventive Services Task Force (USCPSTF), Briss, Saza, Pappaioanou et al. 2000^16^ | Evidence is characterized as strong, sufficient or insufficient | Effect size | Sufficient or large, defined on a case-by-case basis based on Task Force opinion
U.S. Community Preventive Services Task Force (USCPSTF), Briss, Saza, Pappaioanou et al. 2000^16^ | Evidence is characterized as strong, sufficient or insufficient | Expert opinion | Whether used or not
Australian National Health and Medical Research Council (NHMRC) 2009^17^ | Four grades assigned: A=Excellent, B=Good, C=Satisfactory, D=Poor. Grades of “A” can be trusted to guide practice; grades of D concludes the body of evidence is weak and recommendation must be applied with caution. | Evidence base | ‘Evidence hierarchy’ places systematic reviews of RCTs with “low risk of bias” highest
Australian National Health and Medical Research Council (NHMRC) 2009^17^ | | Consistency of evidence | ‘Evidence hierarchy’ places systematic reviews of RCTs with “low risk of bias” highest
Australian National Health and Medical Research Council (NHMRC) 2009^17^ | | Clinical impact | very large, substantial, moderate, slight
Australian National Health and Medical Research Council (NHMRC) 2009^17^ | | Generalizability | Highest grade awarded if “populations studies in body of evidence are the same as the target population for the guideline” (emphasis added)
Australian National Health and Medical Research Council (NHMRC) 2009^17^ | | Applicability | Highest grade awarded if “populations studies in body of evidence are the same as the target population for the guideline” (emphasis added)
UK National Health Service (NHS) Health Development Agency 2005^18^ | Four grades assigned: A, B, C and D. | Efficacy | High quality meta-analyses and systematic reviews of RCTs with very low risk of bias rated highest level of evidence.
UK National Health Service (NHS) Health Development Agency 2005^18^ | Four grades assigned: A, B, C and D. | Evidence of corroboration | Strong evidence of corroboration defined as “Consistent findings in two or more studies of ++ quality carried out within the UK and applicable to the target population, providing evidence on salience and implementation.” ++ is defined as is efficacy above.

Table 3 below summarizes our findings from the application of the six existing evidence frameworks to the three global health exemplars. Household water chlorination had two potential primary outcome measures of interest with which we undertook this exercise: water quality (often objectively measured via water testing) and diarrheal outcomes, which are predominantly self-reported but are often the primary outcomes reported in trials of chlorination studies. Since there was no guidance in the frameworks themselves regarding what types of outcomes are appropriate for their application, we adopted both measures. For PMTCT reviews, we adopted the convention of assessing its body of evidence according to the rate of HIV infection in children assessed at various times during the first year of life. For the literature on Lay or Community Health Workers (CHWs), we adopted the literature's convention of assessing its effectiveness according to the outcome of under-5 morbidity and mortality from any cause.

Table 3 Results on exemplars applied to six evidence frameworks

Outcomes | Tang et al.13 | GRADE14 | HASTE15 | Community Preventive Services Task Force16 | Australian NHMRC17 | NHS Health Development Agency18
Household Water Chlorination
Water Quality | Grade 1 level 1 Strong | ⊕⊕⊕⊕ High quality of evidence | Grade 1- Strong | Strong | “B” - Good | “A”
Diarrhea | Grade 2b level 1 possible | ⊕⊕⊕ Moderate quality of evidence | Grade 2b - Possible | Strong | “C” - Satisfactory | “B”
Preventing Mother-to-Child Transmission, All Regimens Included
HIV infection in child within year of birth | Grade 2b level 1 possible^ | ⊕⊕⊕⊕ High quality of evidence | Grade 1- Strong | Strong | “A” - Excellent | “A”
Lay health workers in primary or community health care to reduce mortality and morbidity in children under age 5, compared with usual care
Mortality and Morbidity | Grade 2b Level 2 Possible^*^ | ⊕⊕ Low quality of evidence | Grade 3 - Insufficient | Strong | “B” - Good | “C”

* Grade 2c Level 2 if repeatability outside Southeast Asia is not considered acceptable.

^ Tang et al. grade for PMTCT is due to strict rule that only interventions with relative risk (RR)>2 qualify as “strong” evidence. If this rule is flexible we would rate PMTCT as “Grade 1 Level 1 Strong” by Tang et al. categorizations.

We focus our attention to the frameworks themselves versus the precise grades assigned to the various exemplars. Operationalizing these frameworks involved a good deal of subjective reasoning and more details for the precise grades assigned to a particular outcome are available in Appendix B.

When measured water quality is the primary outcome from studies of household water chlorination, we generally find that the six frameworks assign a high grade to evidence of its effectiveness. Five of the six frameworks assign their highest possible grade; the Australian National Health and Medical Research Council (NHMRC) framework assigns a grade of “B” (Good). However, when the self-reported diarrheal outcomes are considered, the evidence frameworks generally conclude that the evidence is weak or moderate quality. Only the Community Preventive Services Task Force (CPSTF) framework continues to assign household water chlorination its highest grade for evidence (“Strong”). All of the remaining frameworks downgrade the evidence base by at least one grade in their categorizations, with the evidence classifications now ranging from the highest categorization of “Strong” by the CPSTF framework, to the next-to-lowest grade of “C – Satisfactory” within the Australian NHMRC framework.

For interventions involving community or lay health workers to prevent under-5 morbidity and mortality compared with usual care, the various frameworks generally rate the evidence as being of low or moderate quality with the exception of CPSTF which assigns the highest grade of “Strong.” HASTE, on the other hand, would rate this same body of evidence as grade 3 “Insufficient,” and GRADE also assigns it a “⊕⊕ Low quality of evidence.”

For PMTCT studies, all of the frameworks assign their highest possible grade to the body of evidence with the exception of the framework by Tang et al.,13 which assigns a “Grade 2B, Level 1 Possible.” However, this grade is the result of a strict interpretation of the rule that only interventions with a relative risk (RR) of greater than 2 qualify as “strong.” If there is some flexibility with this strict cutoff both reviewers assigned this exemplar agree its rating would change to the highest grade of “Grade 1 Level 1 Strong.”

Therefore, for two of the four interventions / outcomes (chlorine use and water quality, PMTCT and HIV infection in children within 1 year) there was very good agreement across the frameworks that these interventions were at or near the highest rating on the scale, whereas for the other two interventions / outcomes at least one framework classified the evidence at the top of the rating scale while one or more of the other frameworks classified the evidence at the mid-point or even at the bottom of the rating scale.

In Table 4 we make direct comparisons across the six evidence frameworks according to eight key criteria that we considered to be important for our context of informing community or scale-level policy for global health interventions or programs in developing country settings. These criteria draw from the frameworks themselves as well as considerations by the project team that came about through this exercise. They include (1) how strict or explicit the rules are for classifying the strength of evidence; (2) the magnitude of potential benefits versus harms; (3) what role, if any, context is taken into consideration in evaluating the evidence; (4) how much is known about the details of implementation; (5) whether the ease of implementing the intervention or program is taken into consideration; (6) total costs for the program or intervention; (7) sustainability of the program or intervention, both cost-wise and programmatically; and (8) the ease of operationalizing these frameworks in practice (as, presumably or hopefully, a policymaker may need/want to do).

Table 4 Comparison of six frameworks for assessing the evidence about global health interventions

Frameworks | Domains
Frameworks | Assessment of Strength of Evidence How Explicit? How Strict? | Assessment Of Magnitude Of Benefit vs. Harm | Assessment of Context | Assessment of Implementation How Much is Known? | Assessment of Implementation How Easy is Implementation? | Costs | Sustainability | Comments/Ease of Application
Tang et al.13 | Not as explicit as some others, not as strict as GRADE | Explicit assessment of magnitude of benefit, no explicit assessment of harm | Potentially assessed as part of “widely demonstrated” | Not directly assessed | Could potentially be included in repeatability | Not assessed | Not assessed | Relatively easy to apply, but operationalizing “repeatability” is a challenge
GRADE14 | Very explicit, strictest criteria | Explicit assessment | Not assessed | Not assessed | Not assessed | Not assessed^*^ | Not assessed | Easy to apply, widely used and recognized framework
HASTE15 | Not explicitly assessed, more lenient criteria than GRADE | Not explicitly assessed | Not assessed | Detailed assessment of implementation science data | No explicit assessment of ease of implementation but could readily be incorporated | Not assessed | Not assessed | Relatively easy to apply, some challenge with categories (for example, the situation where efficacy is consistent, biologically plausible and implementation data scarce has no category). The published example contains far more data collection on implementation than what would normally be feasible
Community Preventive Services Task Force16 | Explicitly assessed, more lenient criteria than GRADE | Explicit assessment of benefits with expert judgment for threshold, no explicit assessment of harms | Not assessed | Not assessed | Not assessed | Not assessed | Not assessed | Easy to apply
Australian NHMRC17 | Explicitly assessed, more lenient criteria than GRADE | Explicit assessment | Yes | Not directly assessed, could potentially be included in applicability | Not directly assessed, could potentially be included in applicability | Not assessed, could potentially be included in applicability. | Not directly assessed, could potentially be included in applicability | Very difficult to apply. Potential is large for poor inter-rater reliability.
NHS Health Development Agency18 | Explicitly assessed, criteria approximately as strict as GRADE | Not explicitly assessed | Not directly assessed Indirectly included in corroboration | Included as a component of corroboration | Not directly assessed, but potentially could be part of corroboration | Not assessed | Not assessed | Most difficult to apply. Potential is large for poor inter-rate reliability

* Costs are considered in GRADE's factors to consider when making a recommendation19

None of the frameworks takes into consideration the costs or sustainability of the intervention in assigning its grades to the evidence (Note: GRADE has a separate set of guidance statements for developing recommendations, and include cost). While some frameworks have explicit criteria for assigning grades on strength of evidence,14,16-18 others require more individual interpretation.13,15 Frameworks also differ in whether or not they assess magnitudes of benefits versus harms, and whether or not context is taken into consideration. Similarly, wide differences in whether and the ways in which details of implementation are taken into account exist across frameworks. HASTE calls for a detailed assessment of implementation data while CPSTF, Australian NHMRC, Tang et al. and GRADE do not mention implementation

### Identification and Development of Criteria To Meet Identified Needs or Gaps in Existing Frameworks

The research team presented initial findings of this exercise via teleconference to members of the TEP for feedback on what elements were missing that might be necessary to inform community or scale-level global health policy and programming.

During this discussion, a number of issues arose, including challenges to describing the variability in the intervention (what constitutes household water chlorination is different in terms of variability that what constitutes a lay health care worker), the importance of context when assessing effectiveness of interventions, and the distinction between what is the intervention and what is the implementation. While issues of study design were brought up and discussed, (e.g. the role of randomized studies as opposed to nonrandomized studies) input from the TEP indicated that better information about implementation is needed, regardless of the study design, rather than trying to further argue the merits of randomization. Thus, we determined that the next step for this project was to identify or develop implementation criteria that could be used to supplement any existing frameworks.

We identified three existing sets of criteria for reporting implementation information, from the editors of the journal Implementation Science,1 the Consolidated Framework for Implementation Research3 and the proposed criteria for reporting the development and evaluation of complex interventions in health care (CReDECI).2 Using the TEP-identified issues as a guide, we selected from these the following 10 criteria as potentially relevant to report for implementation of global health interventions, and therefore worth testing in a pilot study. The examples in Table 5 below are ones we developed or adapted from existing examples in the original articles.

Table 5 Global framework—rating implementation criteria

Criterion | Example
Criterion #1 - Intervention Characteristics: Intervention/Program source (From CFIR, Damschroder, 2009)3 | Is the intervention/program externally or internally developed? An intervention/program may be internally developed as a good idea, a solution to a problem, or other grass roots effort, or may be developed by an external entity (such as a foundation or a NGO). Interventions or programs that arise internally from the populations who will be impacted are sometimes more sustainable than externally developed programs dependent on external funding. The perceived legitimacy of the source may also influence implementation.
Criterion #2 - Intervention Characteristics: A description of why the intervention was hypothesized to have an impact on the outcome, according to theory. (From CReDECI, Mohler 2012; also mentioned in Michie, 2009)1,2 | The theoretical basis of the intervention should be clearly stated. This includes the theory on which the intervention is founded as well as, if available, empirical evidence from studies in different settings or countries. For example, The implementation was based on Rogers' Diffusion of Innovation theory, which posits 5 factors of innovation that influence a decision to adopt or reject an innovation: relative advantage, compatibility, complexity or simplicity, trialability, observability. A similar intervention, also based on Rogers' Diffusion of Innovation theory, was successfully implemented in other countries.
Criterion #3 - Intervention Characteristics: Rationale for the aim/essential functions of the intervention/program's components, including the evidence whether the components are appropriate for achieving this goal. This differs from the need to articulate the theory behind the intervention in that the theory posits the general principles (such as Rogers Diffusion of Innovation) while this item is about specific components of the intervention and the effects of the component on specific targets. (From CReDECI, Mohler, 2012; also mentioned in Michie, 2009)1,2 | Explanation/Example: “Our preliminary qualitative field work showed that individual behaviours were influenced by collective behaviours and social norms, and sustained by a complex, multilevel network of relationships within the community. We therefore developed a multilevel strategy targeting: community stakeholders, newborn stake holders, and households with immediate support groups. At each level, the target group consisted of individuals who were identified to have key roles as influencers, decision makers, supporters, and practitioners of newborn care and normative behaviour within the community. The support of community stake holders such as village heads, community leaders, respected members, priests, and teachers was crucial in building trust with the community and ensuring acceptance of the programme. The newborn stakeholder target group included traditional newborn-care providers and birth attendants, unqualified medical practitioners, and, to a lesser extent, health system workers, some of whom had strategic access to the newborn and mother during post-partum confinement, were perceived by the community as domain experts, and played an active part in sustaining targeted practices. Health system workers such as auxillary nurse midwives were engaged only at the community level as part of newborn stakeholder group meetings in order to keep contamination of the intervention into control clusters to a minimum. The household target group included the pregnant woman or mother, who was the primary care provider, but usually not empowered to make decisions; the mother-in-law, who was usually the key decision maker on newborn-care practices; other female members who played supportive roles; and male members, including the father-in-law and husband, who controlled access to the household, made financial and logistical arrangements, and influenced care-seeking decisions. The family's immediate support group included neighbours and relatives who influenced family behaviours and helped with deliveries.”23
Criterion #4 - Outer Setting: External policies and incentives (From CFIR, Damschroder, 2009)3 | How does the health service, intervention, or program relate to country and global health goals? Is the program part of a larger strategy? If so how is it strategically aligned? A country's health policies may influence the implementation of a particular intervention or program.
Criterion #5 - Intervention Characteristics: Detailed description of the intervention/program (From WIDER as described in Michie, 2009)1 The detailed description should include:; a. Characteristics of those delivering the intervention/program (such as a nurse or lay health worker); b. Characteristics of the recipients; c. The setting; d. The mode of delivery (such as face-to-face); e. The intensity of the intervention/program (such as the contact time with participants); f. The duration (such as the number of sessions and their spacing interval over a given period); g. Adherence or fidelity to delivery protocols; h. A detailed description of the intervention/program content provided to each study group
Criterion #6 - Intervention Characteristics: Costs of the intervention and costs associated with implementing the intervention (From CFIR, Damschroder, 2009; CReDECI, Mohler, 2012)2,3 | The cost of the intervention and implementation can influence the adoption and sustainability; interventions maybe more difficult to sustain if they were supported as part of a research study.
Criterion #7 - Population needs (From CFIR, Damschroder, 2009)3 | The extent to which population needs, as well as barriers and facilitators to meet those needs, are accurately known and prioritized. This could include population-based data on causes of morbidity and mortality, political or cultural barriers or facilitators, and/or more locally focused data about local needs, barriers or facilitators.
Criterion #8 - Process of implementation: Description of facilitators or barriers which have influenced the intervention or program's implementation (see #10) revealed by a process assessment. In contrast to the criterion #7 above which assesses barriers and facilitators as inputs to developing the intervention strategy, this criterion assesses the actual barriers and facilitators identified during and after the implementation. (From CReDECI, Mohler, 2012; also mentioned in Michie, 2009)1,2 | “The attitudes of the nursing home managers turned out to be an important factor supporting or impeding the success of the intervention's implementation. The more the managers agreed with the interventions' aim, the better the nursing staff felt supported.”2
Criterion #9 - Description of materials: Description of all materials or tools used for the implementation (From CReDECI, Mohler, 2012)2 | “The primary enablers of behaviour change were paid community-based health workers, who were recruited from the local community based on 12 years or more of education, proficient communication and reasoning skills, commitment towards community work, and references of community stakeholders. They received a combination of classroom based and apprentice ship-based field training over 7 days on knowledge, attitudes, and practices related to essential newborn care within the community, behaviour change management, and trust-building. After training, suitable candidates were closely mentored and supervised by a regional programme supervisor (n=4) responsible for 6–7 trainees, for an additional week before final selection was made.”23
Criterion #10 - Process of Implementation: Description of an assessment of the implementation process (From CReDECI, Mohler 2012)2 | Process assessment is a prerequisite for determining the success of the intervention's implementation and should be an integral part of an assessment of the intervention's effect. For example, “To gain insight into the dissemination and the delivery of the intervention and to draw conclusions about potential barriers and facilitators to implementing the intervention in other settings, data on the implementation process were collected alongside the randomized-controlled trial. Therefore, we assessed the quality of delivery of the interventional components (observed by members of the research team not involved in the delivery of the intervention) and the adherence to study protocol (number and type of deviations from the protocol, using a pilot-tested standardized form). We also analyzed barriers and facilitators for the delivery of intervention's components (focus group interviews with intervention participants).”2

### Pilot Test Draft Criterion

For the pilot testing of the implementation criteria, Tables 6 and 7 present summary findings for household water chlorination, lay health workers, and prevention of mother-to-child-transmission of HIV, respectively, by criterion and by article. More detailed tables assessing what text was found and how we judged it meeting the criteria can be found in Appendix C. Two findings from the summary tables are worth noting: first, the reporting of implementation information is highly variable both within and across articles, with some articles reporting a great deal of information about some criteria and almost nothing about others, and likewise some articles reporting a great deal about most criteria while other articles report almost nothing about most criteria; and second, some criteria were more difficult to judge than others. The criterion on the outer setting, in particular, was one we had a hard time converting into an operational measure. Several of the criteria seemed to be somewhat overlapping, suggesting the possibility that these could be consolidated, for example criterion 5h “A detailed description of the intervention/program content provided to each study group” and criterion 9 “Description of all materials or tools used for the implementation.”

Table 6 Pilot test results of applying draft implementation reporting criteria to published studies of assessments of the effectiveness of three Global Health Intervention exemplars

Criteria | 3 Studies of Household Water Chlorination (Number of Articles Reporting Criterion) | | | 3 Studies of Preventing Mother-to-Child Transmission (Number of Articles Reporting Criterion) | | | 3 Studies of Lay/Community Health Workers (Number of Articles Reporting Criterion) | | | Overall (Number of Articles Reporting Criterion)
| Good | Fair | Poor/None | Good | Fair | Poor/None | Good | Fair | Poor/None | Good | Fair | Poor/None
1. | 1 | 2 | 0 | 2 | 0 | 1 | 1 | 2 | 0 | 4 | 3 | 2
2. | 0 | 1 | 1 | 0 | 3 | 0 | 2 | 0 | 1 | 2 | 4 | 3
3. | 0 | 0 | 3 | 0 | 2 | 1 | 1 | 0 | 2 | 1 | 2 | 6
4. | 0 | 0 | 3 | 0 | 1 | 2 | 0 | 0 | 3 | 0 | 1 | 8
5a. | 1 | 1 | 1 | 1 | 0 | 2 | 1 | 2 | 0 | 3 | 3 | 3
5b. | 3 | 0 | 0 | 2 | 1 | 0 | 2 | 1 | 0 | 6 | 1 | 2
5c. | 3 | 0 | 0 | 2 | 1 | 0 | 3 | 0 | 0 | 8 | 1 | 0
5d. | 3 | 0 | 0 | 2 | 1 | 0 | 1 | 1 | 0 | 6 | 3 | 0
5e. | 2 | 0 | 1 | 0 | 2 | 1 | 1 | 0 | 2 | 3 | 2 | 4
5f. | 2 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 2 | 4 | 2 | 3
5g. | 0 | 2 | 1 | 0 | 1 | 2 | 2 | 1 | 0 | 2 | 4 | 3
5h. | 0 | 1 | 2 | 2 | 1 | 0 | 1 | 1 | 2 | 3 | 3 | 4
6. | 0 | 1 | 2 | 0 | 0 | 3 | 0 | 0 | 3 | 0 | 1 | 8
7. | 0 | 1 | 2 | 1 | 0 | 2 | 1 | 0 | 2 | 2 | 1 | 6
8. | 0 | 0 | 3 | 2 | 0 | 1 | 1 | 0 | 2 | 3 | 0 | 6
9. | 0 | 0 | 3 | 1 | 1 | 1 | 1 | 1 | 1 | 2 | 2 | 5
10. | 0 | 0 | 3 | 0 | 2 | 1 | 1 | 0 | 2 | 1 | 2 | 6
TOTALS | 15 | 10 | 25 | 16 | 17 | 18 | 20 | 9 | 22 | 50 | 35 | 69

Table 7 Number of criteria met, by article

Article | Good | Fair | Poor/None
Household Water Chlorination
Quick et al7 | 4 | 5 | 7
Luby et al 8 | 6 | 2 | 9
Crump et al6 | 5 | 3 | 8
Preventing Mother-to-Child Transmission
Kesho Bora Study Group20 | 6 | 7 | 4
Lussiana et al21 | 0 | 5 | 12
Kim et al22 | 9 | 6 | 2
Lay Health Workers
Kumar et al23 | 12 | 1 | 4
Koyate et al24 | 2 | 5 | 9
Sloan et al25 | 6 | 3 | 7