# References

1 Michie S, Fixsen D, Grimshaw JM, et al. Specifying and reporting complex behaviour change interventions: the need for a scientific method. Implement Sci. 2009;4:40. [pmid: 19607700].
2 Mohler R, Bartoszek G, Kopke S, et al. Proposed criteria for reporting the development and evaluation of complex interventions in healthcare (CReDECI): guideline development. Int J Nurs Stud. Jan. 2012;49(1):40-6. [pmid: 21924424].
3 Damschroder LJ, Aron DC, Keith RE, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4:50. [pmid: 19664226].
4 Arnold BF, Colford JM Jr. Treating water with chlorine at point-of-use to improve water quality and reduce child diarrhea in developing countries: a systematic review and meta-analysis. Am J Trop Med Hyg. Feb. 2007;76(2):354-64. [pmid: 17297049].
5 Clasen T, Schmidt WP, Rabie T, et al. Interventions to improve water quality for preventing diarrhoea: systematic review and meta-analysis. BMJ. Apr. 2007;334(7597):782. [pmid: 17353208].
6 Crump JA, Otieno PO, Slutsker L, et al. Household based treatment of drinking water with flocculant-disinfectant for preventing diarrhoea in areas with turbid source water in rural western Kenya: cluster randomised controlled trial. BMJ. Sep. 3. 2005;331(7515):478. [pmid: 16046440].
7 Quick RE, Venczel LV, Mintz ED, et al. Diarrhoea prevention in Bolivia through point-of-use water treatment and safe storage: a promising new strategy. Epidemiol Infect. Feb. 1999;122(1):83-90. [pmid: 10098789].
8 Luby SP, Agboatwalla M, Painter J, et al. Combining drinking water treatment and hand washing for diarrhoea prevention, a cluster randomised controlled trial. Trop Med Int Health. Apr. 2006;11(4):479-89. [pmid: 16553931].
9 Siegfried N, van der Merwe L, Brocklehurst P, et al. Antiretrovirals for reducing the risk of mother-to-child transmission of HIV infection. Cochrane Database Syst Rev. 2011;(7):CD003510. [pmid: 21735394].
10 Johri M, Ako-Arrey D. The cost-effectiveness of preventing mother-to-child transmission of HIV in low- and middle-income countries: systematic review. Cost Eff Resour Alloc. 2011;9:3. [pmid: 21306625].
11 Chigwedere P, Seage GR, Lee TH, et al. Efficacy of antiretroviral drugs in reducing mother-to-child transmission of HIV in Africa: a meta-analysis of published clinical trials. AIDS Res Hum Retroviruses. Jun. 2008;24(6):827-37. [pmid: 18544018].
12 Lewin S, Munabi-Babigumira S, Glenton C, et al. Lay health workers in primary and community health care for maternal and child health and the management of infectious diseases. Cochrane Database Syst Rev. 2010;(3):CD004015. [pmid: 20238326].
13 Tang KC, Choi BC, Beaglehole R. Grading of evidence of the effectiveness of health promotion interventions. J Epidemiol Community Health. Sep. 2008;62(9):832-4. [pmid: 18701736].
14 Guyatt GH, Oxman AD, Vist GE, et al. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. Apr. 26. 2008;336(7650):924-6. [pmid: 18436948].
15 Baral S, Wirtz A, Sifakis F, et al. The Highest Attainable Standard of Evidence (HASTE) for HIV/AIDS interventions: towards a public health approach to defining evidence. Public Health Rep. Nov. 2012;127(6):572-84. [pmid: 23115382].
16 Briss PA, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services—methods. The Task Force on Community Preventive Services. Am J Prev Med. Jan. 2000;18(1 Suppl):35-43. [pmid: 10806978].
17 National Health and Medical Research Council. NHMRC levels of evidence and grades for recommendations for developers of guidelines. Australia. December. 2009.
18 Wightman A, Ellis S, Cullum A, Sander L, Turley R. Grading evidence and recommendations for public health interventions: developing and piloting a framework. Health Development Agency. 2005. http://www.nice.org.uk/nicemedia/docs/grading_evidence.pdf. December 2012.
19 Guyatt GH, Oxman AD, Kunz R, et al. Incorporating considerations of resources use into grading recommendations. BMJ. May. 24. 2008;336(7654):1170-3. [pmid: 18497416].
20 Safety and effectiveness of antiretroviral drugs during pregnancy, delivery and breastfeeding for prevention of mother-to-child transmission of HIV-1: the Kesho Bora Multicentre Collaborative Study rationale, design, and implementation challenges. Contemp Clin Trials. Jan. 2011;32(1):74-85. [pmid: 20854932].
21 Lussiana C, Clemente SV, Ghelardi A, et al. Effectiveness of a prevention of mother-to-child HIV transmission programme in an urban hospital in Angola. PLoS One. 2012;7(4):e36381. [pmid: 22558455].
22 Kim MH, Ahmed S, Buck WC, et al. The Tingathe programme: a pilot intervention using community health workers to create a continuum of care in the prevention of mother to child transmission of HIV (PMTCT) cascade of services in Malawi. J Int AIDS Soc. 2012;15(4):1-11. [pmid: 22789644].
23 Kumar V, Mohanty S, Kumar A, et al. Effect of community-based behaviour change management on neonatal mortality in Shivgarh, Uttar Pradesh, India: a cluster-randomised controlled trial. Lancet. Sep. 27. 2008;372(9644):1151-62. [pmid: 18926277].
24 Kouyate B, Some F, Jahn A, et al. Process and effects of a community intervention on malaria in rural Burkina Faso: randomized controlled trial. Malar J. 2008;7:50. [pmid: 18364043].
25 Sloan NL, Ahmed S, Mitra SN, et al. Community-based kangaroo mother care to prevent neonatal and infant mortality: a randomized, controlled cluster trial. Pediatrics. May. 2008;121(5):e1047-59. [pmid: 18450847].
26 Guyatt GH, Oxman AD, Kunz R, et al. Going from evidence to recommendations. BMJ. May. 10. 2008;336(7652):1049-51. [pmid: 18467413].
27 Brunetti M, Shemilt I, Pregno S, et al. Grade guidelines: 10. Considering resource use and rating the quality of economic evidence. J Clin Epidemiol. 2012. Aug. 3. [pmid: 22863410].
28 Lewin S, Bosch-Capblanch X, Oliver S, et al. Guidance for evidence-informed policies about health systems: assessing how much confidence to place in the research evidence. PLoS Med. Mar. 2012;9(3):e1001187. [pmid: 22448147].
29 Consort Statement. Consort Transparent Reporting of Trials. Available at: www.consort-statement.org/. 2010. December 2012.