# Objective

The Global Health Evidence Evaluation Framework project is aimed at developing an evidence framework for the purposes of informing efficacious, effective, sustainable global health programs at the community and scale level.