# Methods

This project represents collaboration between the project team and an interdisciplinary group of experts, called the Technical Expert Panel, or TEP. Each key step of the project requires both preparatory work on the part of the project team and then consideration and discussion by the TEP, with synthesis of the TEP discussion and decisions then made by the project team.

Preliminary Key Questions were:

- What is the role of context in the effectiveness and scalability of global health interventions/programs at the community and population level?
- What descriptions of elements of study design and execution are necessary to reach conclusions about effectiveness?
- What descriptions of elements of implementation are necessary to reach conclusions about scalability and sustainability?

The six steps of the project are to:

1. Assemble an interdisciplinary panel of experts.
2. Select a set of “exemplar interventions or programs.” Note “exemplar” means “characteristic of its kind.” These exemplars are needed because they provide the “real world” examples to use when developing and testing frameworks and criteria.
3. Perform a focused literature review on the exemplar interventions, to elucidate what is currently being reported regarding evaluations of the exemplar interventions and to identify gaps in the evidence.
4. Perform an assessment of strengths and limitations of existing frameworks for assessing global health interventions.
5. Identify and/or develop of criteria to meet identified needs or gaps in existing frameworks.
6. Pilot test the draft criteria.

## Assemble an Interdisciplinary Panel of Experts

Using recommendations from the global health community, our partner, and our prior work in program evaluation we were to assemble a panel of experts that included developers and implementers of interventions or programs, methods experts, and policymakers.

## Select a Set of “Exemplar Interventions or Programs”

We identified a diverse set of global health interventions by considering the major causes of morbidity and mortality in developing countries or the major diseases of focus among international global health financing bodies. We developed a draft set of key dimensions for classifying global health interventions in order to map out potential exemplars in order to select a diverse set of exemplars. Having a diverse set of exemplars can help better identify generalizable strengths and weaknesses of existing or proposed frameworks and criteria, akin to the increase in generalizability that comes from enrolling a diverse set of participants in a study of the effectiveness of an intervention. TEP members were asked for input on the dimensions and preferred exemplars. TEP members were also allowed to suggest new potential exemplars that were not included in the initial set of candidates. The dimensions included the following:

- The primary population affected by the disease or the intervention—both in terms of geography as well as demographic (e.g., pregnant women, children under 5, Sub-Saharan Africa, etc.);
- Whether the intervention addresses a communicable or noncommunicable disease;
- Whether the intervention necessitates a one-time delivery or demands a sustained change in behavior or practice on the part of one or more actors;
- Whether the intervention is preventive or a treatment;
- The usual source for the delivery of the intervention—whether the health system, a nongovernmental organization (NGO) or private actors;
- A broad approximation of the level of resources required to supply the intervention (categorized as “low” or “high”);
- Whether the intervention is delivered at the individual or community level (e.g., malaria bednets vs. community boreholes);
- Whether the anticipated health benefits of the intervention are at the individual or community level.

## Focused Literature Review on the Exemplar Interventions for Each of the Three Chosen Global Health Exemplar Interventions

We located published systematic reviews of the effectiveness of the exemplar interventions by conducting a Medline search or using systematic reviews identified by a prior Southern California Evidence-based Practice Center project on HIV in low and middle income countries. For each of these systematic reviews, we then also retrieved the original research studies cited in them, and used both the original studies and the systematic reviews as sources of evidence when applying frameworks and developing criteria.

## Assessment of Strengths and Limitations of Existing Frameworks For Assessing Global Health Interventions

We identified existing frameworks for use in public health or global health interventions by searching Medline up until March 2012, using terms such as “public health intervention,” “strength of evidence,” and “quality of evidence,” and as well as “criteria,” rating,” system,” etc. The vast majority of the results were reviews of the effectiveness of public health interventions (they used the terms in their texts), rather than actual systems to rate the evidence. We pulled the frameworks we were aware of through our work in evidence-based practice, contacted the TEP with what we identified, and asked for additional suggestions. We also reviewed the Web sites of the Cochrane Collaboration, the Campbell Collaboration, the SUPporting POlicy relevant Reviews and Trials (SUPPORT) project, the International Initiative for Impact Evaluation (3IE), the World Health Organizations' EVIPnet (Evidence Informed Policy Networks), SURE (Supporting the Use of Research Evidence for policy in African health systems) and the McMaster Health Forum.

Two members of the research team independently applied the six frameworks to evidence on each of the three exemplar interventions. Disagreements were settled by a group consensus process.

## Identification and Development of Criteria To Meet Identified Needs or Gaps in Existing Frameworks

We presented to our TEP the results of our application of the existing public health/global health frameworks to the evidence about the global health exemplars. The TEP identified the primary gaps in existing frameworks as the lack of information about implementation and sustainability. In this project, we focused on implementation to identify existing implementation criteria (IC), we contacted the editors of the journal Implementation Science seeking their input. The editors referred us to the criteria required by their journal,1 as well as a recent article proposing criteria for complex interventions.2 We also reviewed the Consolidated Framework for Implementation Research,3 which was known to us from our own implementation work and also recommended by our Task Order Officer.

We extracted all criteria from each of these three implementation criteria (IC) frameworks, and then selected those criteria that corresponded to needs we heard expressed by the TEP. We tried to include at least one criterion from each of the five domains in the Consolidated Framework for Implementation Research: intervention characteristics, outer setting, inner setting, characteristics of the individuals involved, and the process of implementation. We ended up selecting 10 implementation criteria for additional testing.

## Pilot Testing of Draft Implementation Criteria

We pilot-tested these 10 implementation criteria by applying them to three articles from the evidence base of each of the three global health exemplars. For each of the 10 criteria and each of the articles, we recorded the exact text that we judged was related to the criterion, or that we could find no text in the article about a particular criterion. One reviewer extracted the data from all three articles for each exemplar and then the results for all were discussed as a group. This text for each criterion was then scored as “good,” “fair,” “poor/none,” based on the degree to which we judged the text meeting the needs of stakeholders regarding that aspect of implementation.