# Limitations

There are some notable limitations of this study. First, we might have missed some global health frameworks in our identification process. Second, not all of these frameworks necessarily had as goals the assessment of information on costs, or contexts, or implementation. Nevertheless, these are crucial aspects of the assessment of evidence about global health interventions, and therefore even if this was not an explicit goal of an existing framework then it is important to note its failure to do so. Third, we only assessed the performance of the existing frameworks with three exemplars, and they may have performed differently on other global health interventions. However, we did purposefully pick our exemplars to represent a diversity of interventions, and furthermore note that our assessment of the frameworks on three exemplars is in general two greater in number than the assessments that were part of the original framework presentation, which usually demonstrated its use with a single example. Furthermore, evaluating the frameworks on additional exemplars is unlikely to change the existing conclusions of variability both within and across frameworks in how evidence is assessed, and will not change the identification of context, costs, and implementation data as important missing domains of these frameworks. Fourth, we relied heavily on input from our technical expert panel, and therefore our results may have been sensitive to the actual participants on our panel and at each stage of the process. Further evaluation of these results with a wider group of stakeholders is warranted. However, these stakeholders' identification of a need for more data about implementation is consistent with the increasing recognition of the importance of implementation reporting in other health-related fields. Fifth, we selected the implementation criteria to assess based on our own judgment, and this would benefit from stakeholder input. Finally, when making judgments about the adequacy of reporting of implementation information we used our own assessments, and this would be better made using the assessments of actual stakeholders, in terms of the adequacy of the reported information to guide decisions about scalability and sustainability.