# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

Robert Balster, M.D.

Jefferson Science Fellow

U.S. Agency for International Development

Washington, DC

Stef Baral, M.D., M.P.H.

Assistant Scientist

Johns Hopkins University

Baltimore, MD

Al Bartlett, M.D.

Director, Saving Newborn Lives Program

Save The Children

Washington, DC

Leonard Bickman, Ph.D.

Professor of Psychology, Psychiatry and Public Policy

Director, Center for Evaluation and Program Improvement (CEPI)

Peabody College

Vanderbilt University

Nashville, TN

Kevin DeCock, M.D.

Director, Center for Global Health

Centers for Disease Control and Prevention

Atlanta, GA

Donna Farley, Ph.D., M.P.H.

Senior Health Policy Researcher

RAND Corporation

Pittsburgh, PA

Geoff Garnett, Ph.D.

Professor of Microparasite Epidemiology

Imperial College London

London, England

Paul Gertler, Ph.D.

Professor of Economics

University of California at Berkeley

Berkeley, CA

Irene Koek, Ph.D.

Director of the Health office for U.S. Agency for International Development

Indonesia

Cliff Lane, M.D., M.P.H.

Professor of Primary Health Care

National Institute of Allergy and Infectious Diseases

National Institutes of Health

Bethesda, MD

Jack Molyneaux, M.D.

Director of Impact Evaluation

Millennium Challenges Corporation

Washington, DC

Pierre Ongolo-Zogo, M.D.

Head, Centre for Development of Best Practices in Health

Yaoundé Central Hospital

Yaoundé, Cameroon

Mead Over, Ph.D.

Senior Vice President

Healthcare Improvement Division

Center for Global Development

Washington, DC

Ariel Pablos-Méndez, M.D., M.P.H.

Assistant Administrator for Global Health

U.S. Agency for International Development

Washington, DC

Tikki Pangestu, Ph.D.

Director, Research Policy & Cooperation

World Health Organization

Geneva, Switzerland

Larry Slutsker, M.D., M.P.H.

Associate Director for Science

Centers for Disease Control and Prevention

Atlanta, GA

Kieran Walshe, Ph.D.

Professor of Health Policy & Management

Manchester Business School

University of Manchester

Manchester, United Kingdom