# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Elizabeth Higgs, M.D., M.I.A., D.T.M.H., U.S. Agency for International Development—Washington, DC