# Discussion

The principal results of this project are:

- Existing frameworks for assessing global health interventions or programs when applied to the same body of evidence for three exemplar interventions yielded somewhat to markedly different assessments of the strength of evidence.
- The most important gap in existing frameworks for assessing global health interventions is the lack of information about implementation, including costs, sufficient for policymakers to make judgments about the sensitivity of effectiveness to differences in context, and the scalability and sustainability of the intervention.
- A pilot test of established criteria for reporting implementation data showed that existing publications of effectiveness of global health interventions vary greatly in the amount of implementation data reported, with more than 40 percent of criteria having poor or absent reporting, and another 20 percent having only fair reporting.

Regarding the first principal result, we also note that even within the same framework, different team members often initially reached different conclusions, largely due to a wide scope for individual interpretation that raises concerns about inter-rater reliability. Also, we note that whereas almost all existing frameworks have explicit assessments of strength of evidence based in some part on study design, almost no frameworks have any assessments of the role of context or costs.

Regarding the third principal result, we note that, like the global health strength of evidence frameworks, the challenge in the operability of many of the criteria raises concern about inter-rater reliability. Additionally, the overlapping nature of some of these criteria indicates that additional work is needed to define what constitutes adequate reporting of implementation details sufficient for stakeholders to make assessments about the sensitivity of effectiveness to context, scalability, and sustainability.

In our judgment, these three results inevitably lead to the conclusion that no existing framework is sufficiently useful for stakeholders to make the kinds of decisions they need to make about global health interventions. Therefore, more work is needed to either adapt one or more existing frameworks, or develop an entirely new framework.

In addition to rating the strength of evidence, (which GRADE refers to as quality of evidence) GRADE has advice for developing recommendations.26 For recommendations, GRADE lists four key factors: the balance between the desirable and undesirable consequences of the alternatives; the quality of the evidence about the desirable and undesirable consequences; uncertainty or variability in values and preferences; and cost. This advice could also be applied to global health decision making. To date, GRADE has produced explicit advice for how to assess resource use;27 and stated that the specific context is critical for considering resource use.19

A recent series of papers from the Task Force on Developing Health Systems Guidance took this advice one step further.28 The Task Force lists a number of factors that may inform decisions about the strength of recommendations regarding policy options, some of which are adopted from GRADE and some of which are in addition to GRADE:

- Whether there is uncertainty about the balance of benefits versus harms and burdens
- The quality of the evidence from the systematic review (very low, low, moderate, high)
- Whether there is uncertainty or variability in values and preferences among stakeholders
- Whether there is uncertainty about whether the net benefits are worth the costs or about resource use
- Whether there is uncertainty about the feasibility of the intervention (or about local factors that influence the translation of evidence into practice, including equity issues)
- Ease of implementation at the systems level, including governance arrangements (e.g., changes needed in regulations), financial arrangements (e.g., the extent to which the options fit with financing models within settings), and implementation strategies (e.g., how to provide the skills and experience needed among implementers or facilitators)
- Socio-political considerations, e.g., how the proposed options relate to existing policies, values within the political system in relation to issues such as equity or privatization, and economic changes

Our project indicates that continuing to develop these factors, particularly about implementation, would be beneficial.