# Conclusions and Future Research Needs

Existing frameworks for evaluating evidence for global health interventions are both too variable to have confidence in their application and do not meet the needs of stakeholders. Additional work needs to be done to develop a framework that will meet stakeholders' needs, and a focus on elements of the reporting of implementation data are a crucial need for a framework to be useful. This will involve both the identification of implementation criteria stakeholders judge to be useful, and then the assessment of whether or not those criteria change or improve decisionmaking. The experience of reporting guidelines for clinical trials offers an example of how a process of evidence and expert opinion can create tools that help the design and reporting of studies of medical interventions.29 Better conducted and reported clinical trials then lead to more informed decisionmaking when developing clinical practice guidelines. The development of reporting guidelines for global health interventions, although a formidable task, has the potential to similarly improve global health decisionmaking.

The reporting of adequate information on implementation will require more text than authors and peer-reviewed journals are currently devoting to the methods section of their publications. It is not coincidental that the article that had the highest number of “good” scores for implementation criteria devoted 1,800 words to describing the intervention and the implementation, which is 50 percent to 80 percent of the word limit many leading journals place on the entire publication. Making additional descriptive material available on the Internet may be one solution to this restriction.