# Background

The global community has collaboratively taken responsibility for advancing health for all and codified this commitment in the Millennium Development Goals. The global effort has enabled standardization of approaches, including the agreement that evidence-based decision making is a norm for health policy, practice, and programs. The U.S. Agency for International Development (USAID) is likewise committed to evidence-based, innovative, efficacious, effective and sustainable global health programs. Evidence based decision making is critical to informing and guiding programming in global health intervention, global health policies, and programs. However, many current evidence evaluation frameworks have evolved from the clinical model where physician decision making is determined by rigorous systematic review of data derived from randomized clinical trials (RCTs) which emphasize efficacy for the individual patient.

Evidence requirements for global health programs are complex, and include three streams: efficacy at the individual level, effectiveness at the population level, and sustainability at the host country level. A standardized approach to evaluation of evidence will strengthen and support global health strategies, programs, and practice optimizing limited resources for maximal health impact.