# Pilot Test of Implementation Reporting Criteria on Three Published Studies for each of Three Exemplars

## Lay Health Workers

Table C.1.1 Criterion Table for Kumar, Effect of community-based behaviour change management on neonatal mortality in Shivgarh, Uttar Pradesh, India: a cluster-randomised controlled trial, Lancet, 2008; 372: 1151-62^1^

Table C.1.2 Criterion Table for Koyate B.; Process and effects of a community intervention on malaria in rural Burkina Faso: randomized controlled trial, Malaria Journal 2008; 7(50)5

Table C.1.3 Criterion Table for Sloan, N.L.; Community-Based Kangaroo Mother Care to Prevent Neonatal and Infant Mortality: A Randomized, Controlled Cluster Trial, Pediatrics 2008; 121; e1047^6^

## Household Water Chlorination

Table C.2.1 Criterion Table for Quick et al.; Diarrhoea prevention in Bolivia through point-of-use water treatment and safe storage: a promising new strategy. 1999. Epidemiol. Infect. 122:83-90^7^

Table C.2.2 Criterion Table for Luby et al.; Combining drinking water treatment and hand washing for diarrhea preventions, a cluster randomized controlled trial. 2006. Tropical Medicine and International Health, 2(4):479-489^8^

Table C.2.3 Criterion Table for Crump et al.; Household based treatment of drinking water with flocculant-disinfectant for preventing diarrhea in areas with turbid source water in rural western Kenya: cluster randomized controlled trial. 2005. BMJ, doi:10.1136/bmj.38512.618681.EO9

## Preventing Mother-to-Child Transmission

Table C.3.1 Criterion Table for Kesho Bora study group, 2010. Safety and effectiveness of antiretroviral drugs during pregnancy, delivery, and breastfeeding for prevention of mother to children transmission of HIV-1: The Kesho Bora Multicentre Collaborate Study rational, design, and implementation challenges.10

Table C.3.2 Criterion Table for Lussiana, 2012. Effectiveness of a Prevention of Mother-to-Child HIV Transmission Programme in an Urban Hospital in Angola11

Table C.3.3 Criterion Table for Kim MH, Ahmed S, Buck WC, Preidis GA, Hosseinipour MC, Bhalakia A, Nanthuru D, Kazembe PN, Chimbwandira F, Giordano TP, Chiao EY, Schutze GE, Kline MW. The Tingathe programme: a pilot intervention using community health workers to create a continuum of care in the prevention of mother to child transmission of HIV (PMTCT) cascade of services in Malawi. J Int AIDS Soc. 2012;15(4):1-11. PMID 22789644^12^

## References

1 Kumar V, Mohanty S, Kumar A, et al. Effect of community-based behaviour change management on neonatal mortality in Shivgarh, Uttar Pradesh, India: a cluster-randomised controlled trial. Lancet. 2008;372(9644):1151-62. [pmid: 18926277].
2 Damschroder LJ, Aron DC, Keith RE, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4:50. [pmid: 19664226].
3 Mohler R, Bartoszek G, Kopke S, et al. Proposed criteria for reporting the development and evaluation of complex interventions in healthcare (CReDECI): guideline development. Int J Nurs Stud. 2012;49(1):40-6. [pmid: 21924424].
4 Michie S, Fixsen D, Grimshaw JM, et al. Specifying and reporting complex behaviour change interventions: the need for a scientific method. Implement Sci. 2009;4:40. [pmid: 19607700].
5 Kouyate B, Some F, Jahn A, et al. Process and effects of a community intervention on malaria in rural Burkina Faso: randomized controlled trial. Malar J. 2008;7:50. [pmid: 18364043].
6 Sloan NL, Ahmed S, Mitra SN, et al. Community-based kangaroo mother care to prevent neonatal and infant mortality: a randomized, controlled cluster trial. Pediatrics. 2008;121(5):e1047-59. [pmid: 18450847].
7 Quick RE, Venczel LV, Mintz ED, et al. Diarrhoea prevention in Bolivia through point-of-use water treatment and safe storage: a promising new strategy. Epidemiol Infect. 1999;122(1):83-90. [pmid: 10098789].
8 Luby SP, Agboatwalla M, Painter J, et al. Combining drinking water treatment and hand washing for diarrhoea prevention, a cluster randomised controlled trial. Trop Med Int Health. 2006;11(4):479-89. [pmid: 16553931].
9 Crump JA, Otieno PO, Slutsker L, et al. Household based treatment of drinking water with flocculant-disinfectant for preventing diarrhoea in areas with turbid source water in rural western Kenya: cluster randomised controlled trial. BMJ. 2005;331(7515):478. [pmid: 16046440].
10 Safety and effectiveness of antiretroviral drugs during pregnancy, delivery and breastfeeding for prevention of mother-to-child transmission of HIV-1: the Kesho Bora Multicentre Collaborative Study rationale, design, and implementation challenges. Contemp Clin Trials. 2011;32(1):74-85. [pmid: 20854932].
11 Lussiana C, Clemente SV, Ghelardi A, et al. Effectiveness of a prevention of mother-to-child HIV transmission programme in an urban hospital in Angola. PLoS One. 2012;7(4):e36381. [pmid: 22558455].
12 Kim MH, Ahmed S, Buck WC, et al. The Tingathe programme: a pilot intervention using community health workers to create a continuum of care in the prevention of mother to child transmission of HIV (PMTCT) cascade of services in Malawi. J Int AIDS Soc. 2012;15(4):1-11. [pmid: 22789644].