# Using Six Different Frameworks To Assess the Evidence for Three Examples of Health Interventions or Programs

## Tang Framework1

- Grade 1 (strong)
  What works is known: a high association is shown; and repeatability is widely demonstrated
  - Level 1 how it works is known
  - Level 2 how it works is not known
- Grade 2 (weak)
  What works is known: but a low association is shown; and/or repeatability is limited
  - Level 1 how it works is known
  - Level 2 how it works is not known
- Grade 3 (insufficient)
  What works is not known: evidence is insufficient

Table B.1 Grading of evidence based on association, repeatability and causal mechanism

3–Grades | 3–Grades expanded | Association | Repeatability | How it works
1 (strong) | 1 (strong) | High | Wide | Known Not known
1 (strong) | 2A (probable) | High | Limited | Known Not known
2 (weak) | 2B (possible) | Low | Wide | Known Not known
2 (weak) | 2C (limited) | Low | Limited | Known Not known
3 (insufficient) | 3 (insufficient) | None | None | Not known

Household Water Chlorination

TANG Framework
What works is known or what works is not known | Known: at least 4 RCTs plus other controlled trials, pooled analyses show reduction in diarrhea of RR = 0.61 or 0.71
Association (defined in TANG as RR ≥ 2) | If diarrhea is the outcome, then it is low (RR = 0.61 – 0.71). If fecal coliforms is the outcome, then it is high (RR = 0.20).
Repeatability (and/or consistency^*^) | Efficacy/effectiveness shown in 4 continents. Seems like this should be “repeatability has been widely demonstrated”.
How it works | Known . Chlorine kills germs, germs cause diarrhea.
Overall classification | Grade 1 (strong) level 1[if fecal coliforms is the outcome], Grade 2B (possible) level 1 if diarrhea is the outcome

* Consistency is used as the term in the abstract, but repeatability is the term in the text, and these seem like potentially different constructs.

Lay health workers in primary or community health care to reduce mortality and morbidity in children under age 5, compared to usual care

TANG Framework
What works is known or what works is not known | Known: 7 RCTs, 6 of which favor the intervention, 2 of which produced statistically significant results, the pooled effect is statistically significant.
Association (defined in TANG as RR ≥ 2) | Low (RR= 0.86)
Repeatability (and/or consistency^*^) | Effectiveness has been studied in 6 different countries, but all but one is in southeast Asia.
How it works | Not known. Interventions have been heterogeneous, there are no data about direct process-outcome links.
Overall classification | Grade 2b Level 2 (if repeatability outside southeast Asia is acceptable) Grade 2c Level 2 (if repeatability outside southeast Asia is considered acceptable)

* Consistency is used as the term in the abstract, but repeatability is the term in the text, and these seem like potentially different constructs.

PMTCT

TANG Framework
What works is known or what works is not known | Known: Several high quality meta-analyses show significant results.
Association (defined in TANG as RR ≥ 2) | Yes, High; Transmission reduced by 40 to 80% depending on regimen.
Repeatability (and/or consistency^*^) | Wide. Consistent results. Has been studied in many RCTs in Sub-Saharan Africa, Southeast Asia, and Latin America, after first being tested in developed countries.
How it works | Mechanism is well understood at the molecular basis.
Overall classification | Grade 1 (Strong) Level 1

* Consistency is used as the term in the abstract, but repeatability is the term in the text, and these seem like potentially different constructs.

## GRADE Framework2

Table B.2 A summary of GRADE's approach to rating quality of evidence

Study Design | Initial quality of a body of evidence | Lower if | Higher if | Quality of a body of evidence
Randomized Trials | High [image] | Risk of Bias; - - 1 Serious; - - 2 Very serious; Inconsistency; - - 1 Serious; - - 2 Very serious | Large effect; - + 1 Large; - + 2 Very large; Dose response; - + 1 Evidence of a gradient | High (four plus: ⊕ ⊕ ⊕ ⊕) Moderate (three plus: ⊕ ⊕ ⊕○)
Observational studies | Low [image] | Indirectness; - - 1 Serious; - - 2 Very serious; Imprecision; - - 1 Serious; - - 2 Very serious; Publication bias; - - 1 Likely; - - 2 Very likely | All plausible residual confounding; - + 1 Would reduce a Demonstrated effect; - + 1 Would suggest a Spurious effect if no effect was observed | Low (two plus: ⊕ ⊕ ○ ○) Very low (one plus: ⊕ ○ ○ ○)

Table B.3 Significance of the four levels of evidence

Quality Level | Current Definition
High | We are very confident that the true effect lies close to that of the estimate of the effect
Moderate | We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different
Low | Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect
Very Low | We have very little confidence in the effect estimate: The true effect is likely to be substantially different from the estimate of effect

Household Water Chlorination

No. of studies | Design | | Limitations | Inconsistency | | Indirectness | Imprecision | Other considerations
Water Quality
5 + | Controlled Trials | | No serious limitations | No serious inconsistency | | No serious indirectness | No serious imprecision | Strong association
Diarrhea
5+ | Controlled Trials | | Serious or very serious limitations (blinding) | No serious inconsistency | | No serious indirectness | No serious imprecision | None

Summary of findings
| | Effect | | | Quality | | Importance
Water Quality
| | RR = 0.20 (95% CI 0.13 – 0.30) | | | High ⊕ ⊕ ⊕ ⊕ | | Important
Diarrhea
| | RR = 0.71 (95% CI 0.58 – 0.87) | | | Moderate : ⊕ ⊕ ⊕ ○ | | Critical

Lay health workers in primary or community health care to reduce mortality and morbidity in children under age 5, compared to usual care

No. of studies | Design | | Limitations | Inconsistency | | Indirectness | Imprecision | Other considerations
Reduce Morbidity / Mortality
7 | Randomized Trials | | Serious risk of bias | Serious inconsistency | | No serious indirectness | No serious imprecision | None

Summary of findings
| | Effect | | | Quality | | Importance
Reduce Morbidity / Mortality
| | RR = 0.86 (95% CI 0.75 – 0.99) | | | Low ⊕ ⊕ ○ ○ | | Critical

PMTCT

No. of studies | Design | | Limitations | Inconsistency | | Indirectness | Imprecision | Other considerations
HIV Infection in Child
15 | All RCTS | | No serious limitations | No serious inconsistency | | No serious indirectness | No serious imprecision | None

Summary of findings
| | Effect | | | Quality | | Importance
| | Transmission of HIV reduced by 40% to 80% depending on regimen | | | High ⊕ ⊕ ⊕ | | High. Huge population affected in Sub Saharan Africa.

## HASTE Framework3

Table B.4 Highest Attainable Standard of Evidence System for HIV Interventions (HASTE)

Grade Level | Strength of Recommendation | Explanation
Grade 1 | Strong | - Efficacy is Consistent; - Biologically plausible; - Implementation Data Available
Grade 2a | Probable | - Limited Efficacy Data; - Biologically Plausible
Grade 2b | Possible | - Efficacy is inconsistent; - Biologically plausible; - Consensus from Implementation Science Data
Grade 2c | Pending | - Ongoing Definitive Trials; - Plausibility
Grade 3 | Insufficient | - Inconsistent Data; - Undefined Plausibility; - Paucity of Implementation Science Data
Grade 4 | Inappropriate | - Consistent data demonstrating lack of efficacy; - Consensus from Implementation Data of Inappropriate Intervention

Household Water Chlorination

HASTE Framework
Efficacy is Consistent | Yes, based on the forest plot in 2 meta-analyses
Implementation science data | We can only use what is in the included studies or implementation science studies from the Arnold list of excludes. We rate this as “available”, certainly implementation is described better in these studies than in many studies medical interventions.
Biologically Plausible | Yes
Overall classification based on HASTE | Grade 1 Strong

Lay health workers in primary or community health care to reduce mortality and morbidity in children under age 5, compared to usual care

HASTE Framework
Efficacy is Consistent | Yes, based on the forest plot in the Cochrane Review.
Implementation science data | We can only use what is in the included studies in the Cochrane Review. These studies give quite detailed explanations of how the interventions were implemented. We rate this as “available”.
Biologically Plausible | Unclear
Overall classification based on HASTE | Unclear how to clarify this. “Undefined plausibility” appear in Grade 3, insufficient, but the other descriptor in that case say “inconsistent data” and “paucity of implementation science data”) don't accurately characterize the evidence.

PMTCT

HASTE Framework
Efficacy is consistent | Yes, based on forest plots in multiple meta-analyses.
Implementation science data | Exists, focuses on barriers, costs
Biologically Plausible | Yes
Overall classification based on HASTE | Grade 1, Strong

## Community Preventive Services Task Force Framework4

Table B.5 Assessing the strength of a body of evidence on effectiveness of population-based interventions in the Guide to Community Preventive Services

Evidence of effectiveness^a^ | Execution—good or fair^b^ | Design Suitability—Greatest, moderate, or least | Number of studies | Consistent^c^ | Effect size^d^ | Expert opinion^e^
Strong | Good | Greatest | At Least 2 | Yes | Sufficient | Not used
Strong | Good | Greatest or Moderate | At Least 5 | Yes | Sufficient | Not used
Strong | Good or Fair | Greatest | At Least 5 | Yes | Sufficient | Not used
Meet Design, Execution, Number and Consistency Criteria for Sufficient But Not Strong Evidence | | | | | Large | Not used
Sufficient | Good | Greatest | 1 | Not Applicable | Sufficient | Not used
Sufficient | Good or Fair | Greatest or Moderate | At Least 3 | Yes | Sufficient | Not used
Sufficient | Good or Fair | Greatest, Moderate or Least | At Least 5 | Yes | Sufficient | Not used
Expert Opinion | Varies | Varies | Varies | Varies | Sufficient | Supports a Recommendation
Insufficient^f^ | A. Insufficient | Designs or Execution | B. Too Few Studies | C. Inconsistent | D. Small | E. Not Used

a The categories are not mutually exclusive; a body of evidence meeting criteria for more than one of these should be categorized in the highest possible category.

b Studies with limited execution are not used to assess effectiveness.

c Generally consistent in direction and size.

d Sufficient and large effect sizes are defined on a case-by-case basis and are based on Task Force opinion.

e Expert opinion will not be routinely used in the Guide but can affect the classification of a body of evidence as shown.

f Reasons for determination that evidence is insufficient will be described as follows: A. Insufficient designs or executions, B. Too few studies, C.Inconsistent. D. Effect size too small, E. Expert opinion not used. These categories are not mutually exclusive and one or more of these will occur when a body of evidence fails to meet the criteria for strong or sufficient evidence.

Table B.6 Suitability of study design for assessing effectiveness in the Guide to Community Preventive Services

Suitability | Attributes
Greatest | Concurrent comparison groups and prospective measurement of exposure and outcome
Moderate | All retrospective designs or multiple pre or post measurements but no concurrent comparison group
Least | Single pre and post measurements and no concurrent comparison group or exposure and outcome measured in a single group at the same point in time

Household Water Chlorination

Community Preventive Services Task Force Framework
Household Water Chlorination
Water Quality
Execution | Good or Fair
Design suitability | Greatest
Number of studies | At least 5
Consistent | Generally consistent in direction and size
Effect size | Sufficient
Overall evidence of effectiveness | Strong
Diarrhea
Execution | Good or Fair
Design suitability | Greatest
Number of studies | At least 5
Consistent | Generally consistent in direction and size
Effect size | Sufficient
Overall evidence of effectiveness | Strong

Lay health workers in primary or community health care to reduce mortality and morbidity in children under age 5, compared to usual care

Community Preventive Services Task Force Framework
Execution | Good or Fair
Design suitability | Greatest
Number of studies | At least 5
Consistent | Generally consistent in direction and size
Effect size | Sufficient
Overall evidence of effectiveness | Strong

PMTCT

Community Preventive Services Task Force Framework
Execution | Good
Design suitability | Greatest (RCTs)
Number of studies | At least 5
Consistent | Yes
Effect size | Large
Overall evidence of effectiveness | Strong

## Australian NHMRC Framework5

Table B.7 Body of evidence matrix

Component | A | B | C | D
| Excellent | Good | Satisfactory | Poor
Evidence base^a^ | one or more level I studies with a low risk of bias or several level II studies with a low risk of bias | one or two level II studies with a low risk of bias or a SR/several level III studies with a low risk of bias | one or two level III studies with a low risk of bias, or level I or II studies with a moderate risk of bias | level IV studies, or level I to III studies/SRs with a high risk of bias
Consistency^b^ | all studies consistent | most studies consistent and inconsistency may be explained | some inconsistency reflecting genuine uncertainty around clinical question | evidence is inconsistent
Clinical impact | very large | substantial | moderate | slight or restricted
Generalizability | population/s studied in body of evidence are the same as the target population for the guideline | population/s studied in the body of evidence are similar to the target population for the guideline | population/s studied in body of evidence differ to target population for guideline but it is clinically sensible to apply this evidence to target population^c^ | population/s studied in body of evidence differ to target population and hard to judge whether it is sensible to generalise to target population
Applicability | directly applicable to Australian healthcare context | applicable to Australian healthcare context with few caveats | probably applicable to Australian healthcare context with some caveats | not applicable to Australian healthcare context

SR = systematic review; several = more than two studies

a Level of evidence determined from the NHMRC evidence hierarchy

b If there is only one study, rank this component as ‘not applicable’.

c For example, results in adults that are clinically sensible to apply to children OR psychosocial outcomes for one cancer that may be applicable to patients with another cancer

Table B.8 Definition of NHMRC grades of recommendations

Grade of recommendation | Description
A | Body of evidence can be trusted to guide practice
B | Body of evidence can be trusted to guide practice in most situations
C | Body of evidence provides some support for recommendation(s) but care should be taken in its application
D | Body of evidence is weak and recommendation must be applied with caution

Table B.9 NHMRC Evidence Hierarchy: designations of ‘levels of evidence’ according to type of research question (including explanatory notes)

Level | Intervention^a^ | Diagnostic Accuracy^b^ | Prognosis | Aetiology^c^ | Screening Intervention
I^d^ | A systematic review of level II studies | A systematic review of level II studies | A systematic review of level II studies | A systematic review of level II studies | A systematic review of level II studies
II | A randomized controlled trial | A study of test accuracy with: an independent, blinded comparison with a valid reference standard,^e^ among non-consecutive persons with a defined clinical presentation^f^ | A prospective cohort study^g^ | A prospective cohort study | A randomized controlled trial
III-1 | A pseudorandomized controlled trial (i.e. alternate allocation or some other method) | A study of test accuracy with: an independent, blinded comparison with a valid reference standard,^e^ among non-consecutive persons with a defined clinical presentation^f^ | All or none^h^ | All or none^h^ | A pseudorandomized controlled trial (i.e. alternate allocation or some other method)
III-2 | A comparative study with concurrent controls:; - Non-randomized, experimental trial^i^; - Cohort study; - Case-control study; - Interrupted time series with a control group | A comparison with reference standard that does not meet the criteria required for Level II and III-1 evidence | Analysis of prognostic factors amongst persons in a single arm of a randomized controlled trial | A retrospective cohort study | A comparative study with concurrent controls:; - Non-randomized, experimental trial; - Cohort study; - Case-control study
III-3 | A comparative study without concurrent controls:; - Historical control study; - Two or more single arm Study^j^; - Interrupted time series without a parallel control group | Diagnostic case-control Study^f^ | A retrospective cohort study | A case-control study | A comparative study without concurrent controls:; - Historical control study; - Two or more single arm Study
IV | Case series with either post-test or pre-test/post-test outcomes | Study of diagnostic yield (no reference standard)^k^ | Case series, or cohort study of persons at different stages of disease | A cross-sectional study or case series | Case series

Explanatory notes

a Definitions of these study designs are provided on pages 7-8 How to use the evidence: assessment and application of scientific evidence (NHMRC 2000b) and in the accompanying Glossary.

b These levels of evidence apply only to studies of assessing the accuracy of diagnostic or screening tests. To assess the overall effectiveness of a diagnostic test there also needs to be a consideration of the impact of the test on patient management and health outcomes (Medical Services Advisory Committee 2005, Sackett and Haynes 2002). The evidence hierarchy given in the ‘Intervention’ column should be used to assess the impact of a diagnostic test on health outcomes relative to an existing method of diagnosis/comparator test(s). The evidence hierarchy given in the ‘Screening’ column should be used to assess the impact of a screening test on health outcomes relative to no screening or opportunistic screening.

c If it is possible and/or ethical to determine a causal relationship using experimental evidence, then the ‘Intervention’ hierarchy of evidence should be utilised. If it is only possible and/or ethical to determine a causal relationship using observational evidence (eg. cannot allocate groups to a potential harmful exposure, such as nuclear radiation), then the ‘Aetiology’ hierarchy of evidence should be utilised.

d A systematic review will only be assigned a level of evidence as high as the studies it contains, excepting where those studies are of level II evidence. Systematic reviews of level II evidence provide more data than the individual studies and any meta-analyses will increase the precision of the overall results, reducing the likelihood that the results are affected by chance. Systematic reviews of lower level evidence present results of likely poor internal validity and thus are rated on the likelihood that the results have been affected by bias, rather than whether the systematic review itself is of good quality. Systematic review quality should be assessed separately. A systematic review should consist of at least two studies. In systematic reviews that include different study designs, the overall level of evidence should relate to each individual outcome/result, as different studies (and study designs) might contribute to each different outcome.

e The validity of the reference standard should be determined in the context of the disease under review. Criteria for determining the validity of the reference standard should be pre-specified. This can include the choice of the reference standard(s) and its timing in relation to the index test. The validity of the reference standard can be determined through quality appraisal of the study (Whiting et al 2003).

f Well-designed population based case-control studies (eg. population based screening studies where test accuracy is assessed on all cases, with a random sample of controls) do capture a population with a representative spectrum of disease and thus fulfil the requirements for a valid assembly of patients. However, in some cases the population assembled is not representative of the use of the test in practice. In diagnostic case-control studies a selected sample of patients already known to have the disease are compared with a separate group of normal/healthy people known to be free of the disease. In this situation patients with borderline or mild expressions of the disease, and conditions mimicking the disease are excluded, which can lead to exaggeration of both sensitivity and specificity. This is called spectrum bias or spectrum effect because the spectrum of study participants will not be representative of patients seen in practice (Mulherin and Miller 2002).

g At study inception the cohort is either non-diseased or all at the same stage of the disease. A randomised controlled trial with persons either non-diseased or at the same stage of the disease in both arms of the trial would also meet the criterion for this level of evidence.

h All or none of the people with the risk factor(s) experience the outcome; and the data arises from an unselected or representative case series which provides an unbiased representation of the prognostic effect. For example, no smallpox develops in the absence of the specific virus; and clear proof of the causal link has come from the disappearance of small pox after large-scale vaccination.

i This also includes controlled before-and-after (pre-test/post-test) studies, as well as adjusted indirect comparisons (ie. utilise A vs B and B vs C, to determine A vs C with statistical adjustment for B).

j Comparing single arm studies ie. case series from two studies. This would also include unadjusted indirect comparisons (ie. utilise A vs B and B vs C, to determine A vs C but where there is no statistical adjustment for B).

k Studies of diagnostic yield provide the yield of diagnosed patients, as determined by an index test, without confirmation of the accuracy of this diagnosis by a reference standard. These may be the only alternative when there is no reliable reference standard.

Note A: Assessment of comparative harms/safety should occur according to the hierarchy presented for each of the research questions, with the proviso that this assessment occurs within the context of the topic being assessed. Some harms (and other outcomes) are rare and cannot feasibly be captured within randomised controlled trials, in which case lower levels of evidence may be the only type of evidence that is practically achievable; physical harms and psychological harms may need to be addressed by different study designs; harms from diagnostic testing include the likelihood of false positive and false negative results; harms from screening include the likelihood of false alarm and false reassurance results.

Note B: When a level of evidence is attributed in the text of a document, it should also be framed according to its corresponding research question eg. level II intervention evidence; level IV diagnostic evidence; level III-2 prognostic evidence.

Note C: Each individual study that is attributed a “level of evidence” should be rigorously appraised using validated or commonly used checklists or appraisal tools to ensure that factors other than study design have not affected the validity of the results.

Source: Hierarchies adapted and modified from: NHMRC 1999; Bandolier 1999; Lijmer et al. 1999; Phillips et al. 2001.

Household Water Chlorination

Australian NHMRC Framework | Water Quality | Diarrhea
Evidence of effectiveness | A - one or two level 1 (actually two) studies with a low risk of bias | A
Consistency | A - All studies consistent | B - most studies consistent and inconsistency may be explained
Clinical Impact | Substantial | Substantial
Generalizability | B | C
Applicability | C - For this application we'll say “probably applicable with some caveats” | C - For the purpose we'll assume a rural area in a MIC
Overall classification based on Australian NHMRC | B | C

Lay health workers in primary or community health care to reduce mortality and morbidity in children under age 5, compared to usual care

Australian NHMRC Framework
Evidence of effectiveness | B – One or two (actually 1) level 2 studies with a low risk of bias
Consistency | B – Most studies consistent and inconsistency may be explained
Clinical Impact | C - Moderate
Generalizability | B - population/s studied are similar to the target population
Applicability | C – Probably applicable with some caveats
Overall classification based on Australian NHMRC | B – “Good”

PMTCT

Australian NHMRC Framework
Evidence of effectiveness | A - Excellent, several high quality systematic reviews of RCTs
Consistency | B – Good. Very consistent – only inconsistencies in effect are explained. Studies with lower effect sizes conducted in breastfeeding women
Clinical Impact | A – Very large, possibly millions worldwide
Generalizability | B – Has been studied in Latin America, Asia, Sub-Saharan Africa
Applicability | C – In clinical trials, drugs are provided for free. In reality, free meds aren't available to everyone who needs them.
Overall classification based on Australian NHMRC | B - Body of evidence can be trusted to guide practice in most situations
Limitations | Doesn't consider cost directly, unless taken into consideration as part of “applicability”

## NHS Health Development Agency Framework6

Table B.10 Pilot public health evidence grading scheme: classification of recommendation

Class | Basis for decision^*^
A [PH] | At least one 1++ study or consistent findings in a body of studies^**^ principally rated as 1+ for efficacy^***^, with strong or moderate evidence of corroboration OR Consistent findings in a body of 2++ studies for efficacy, with strong evidence of corroboration
B [PH] | At least one 1++ study or consistent findings in a body of studies principally rated as 1+ for efficacy, with limited/no evidence of corroboration OR A single 1+ study for efficacy, with strong or moderate evidence of corroboration OR A single 2++ study or consistent findings in a body of studies principally rated as 2+ for efficacy, with strong evidence of corroboration OR Consistent findings in a body of studies principally rated as 2++ for efficacy, with moderate evidence of corroboration
C [PH] | Consistent findings in a body of studies principally rated as 2++ for efficacy, with limited/no evidence of corroboration OR A single 2++ study or consistent findings in a body of studies principally rated 2+ for efficacy, with moderate evidence of corroboration OR A single 2+ study for efficacy, with strong evidence of corroboration OR A body of level 3 or 4 evidence for efficacy, with strong evidence of corroboration
D [PH] | A single 2++ study or consistent findings in a body of studies principally rated 2+ for efficacy, with limited/no evidence of corroboration OR A single 2+ study for efficacy, with moderate evidence for corroboration OR A body of level 3 or 4 evidence of efficacy, with moderate/limited evidence of corroboration OR Formal consensus
D [GPP] | A recommendation based on experience of best practice by health professionals and expert groups

* See Tables 2 and 3 for key to study type, quality and strength of evidence.

** Body of studies = 3 or more, or a systematic review.

*** For national environmental/socio-political interventions, a body of 2+ studies is acceptable.

[PH] public health; [GPP] Good Practice Point.

Source: adapted from SIGN (2001).

Table B.11 Evidence of the efficacy of an intervention – did it work?

Level of evidence | Type of evidence
1++ | High quality meta-analyses, systematic reviews of RCTs (including cluster RCTs), or RCTs with a very low risk of bias
1+ | Well conducted meta-analyses, systematic reviews of RCTs, or RCTs with a low risk of bias
1–^*^ | Meta-analyses, systematic reviews of RCTs, or RCTs with a high risk of bias
2++ | High quality systematic reviews of, or individual high quality non-randomised intervention studies (controlled non-randomised trial, controlled before-and-after, interrupted time series), comparative cohort and correlation studies with a very low risk of confounding, bias or chance
2+ | Well conducted, non-randomised intervention studies (controlled non-randomised trial, controlled before-and-after, interrupted time series), comparative cohort and correlation studies with a low risk of confounding, bias or chance
2–^*^ | Non-randomised intervention studies (controlled non-randomised trial, controlled before-and-after, interrupted time series), comparative cohort and correlation studies with a high risk of confounding, bias or chance
3 | Non-analytical studies (eg case reports, case series)
4 | Expert opinion, formal consensus

* Studies with a level of evidence (–) should not be used as basis for making recommendations.

Source: adapted from SIGN (2001).

Table B.12 Evidence for corroboration – will it work? (evidence to support implementation in the UK today) and does it matter? (evidence of salience and relevant outcomes for UK populations today)

Strength of evidence | Type of evidence
Strong | Consistent findings in two or more studies of ++ quality carried out within the UK and applicable* to the target population, providing evidence on salience and implementation
Moderate | One ++ study or consistent findings in two or more studies of + quality carried out within the UK and applicable to the target population OR
| Two or more ++ studies from outside the UK but applicable to the target population, providing evidence on salience and implementation
Limited | Only one + study from the UK, two or more studies with inconsistent findings (on balance providing evidence of benefit or harm) or studies of + quality from outside the UK
No evidence | No study of acceptable quality, inconsistent findings (on balance providing no useful evidence) or no relevant research available

Household Water Chlorination

NHS Health Development Agency Framework
Evidence of efficacy – did it work? | Class 1++ or class 1+ for water quality Class 2++ for diarrhea
Evidence for corroboration – will it work? (evidence to support implementation) And does it matter? (evidence of salience to the target population) | If the studies are ++ (meaning “high quality” with a very low risk of bias, confounding or chance); if not this strength then “limited” if the studies are only “well conducted” with a low risk of bias, confounding, or chance.
Overall classification using NHS Health Development Agency | “A” for water quality “B” for diarrhea

Lay health workers in primary or community health care to reduce mortality and morbidity in children under age 5, compared to usual care

NHS Health Development Agency Framework
Evidence of efficacy – did it work? | A single 2++ study (Cochrane meta-analysis) with moderate evidence of corroboration.
Evidence for corroboration – will it work? (evidence to support implementation) And does it matter? (evidence of salience to the target population) | A single 2++ study (Cochrane meta-analysis) with moderate evidence of corroboration.
Overall classification using NHS Health Development Agency | “C”

PMTCT

NHS Health Development Agency Framework
Evidence of efficacy – did it work? | 1++, several high quality meta-analyses of RCTs
Evidence for corroboration – will it work? (evidence to support implementation) And does it matter? (evidence of salience to the target population) | Studies are conducted in the target population in low income countries.
Overall classification using NHS Health Development Agency | “A”

## References

1 Tang KC, Choi BC, Beaglehole R. Grading of evidence of the effectiveness of health promotion interventions. J Epidemiol Community Health. 2008;62(9):832-4. [pmid: 18701736].
2 Balshem H, Helfand M, Schunemann HJ, et al. GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011;64(4):401-6. [pmid: 21208779].
3 Baral S, Wirtz A, Sifakis F, et al. The Highest Attainable Standard of Evidence (HASTE) for HIV/AIDS Interventions: Towards A Public Health Approach to Defining Evidence. Public Health Reports. in press.
4 Briss PA, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services--methods. The Task Force on Community Preventive Services. Am J Prev Med. 2000;18(1 Suppl):35-43. [pmid: 10806978].
5 National Health and Medical Research Council. NHMRC levels of evidence and grades for recommendations for developers of guidelines. Australia. December. 2009.
6 Wightman A, Ellis S, Cullum A, et al. Grading evidence and recommendations for public health interventions: developing and piloting a framework. Health Development Agency. 2005. http://www.nice.org.uk/nicemedia/docs/grading_evidence.pdf. Dec 2012.