# Overview of Potential Exemplars

Classification Dimensions

Dimension/Examples | Bednets for Malaria | Malaria Vaccine | MTCT for HIV | Household Water Chlorination | Condom Distribution | HIV RX as Prevention | Oral Rehydration Salts (ORS) | Handwashing | ARI/ Improved Cook Stove Adoption | Source Water Improvement
Populations affected by a disease
- maternal health, adults, elderly, children | all | all | pregnant women | primarily children under 5 (diarrhea) | adults | people with/without HIV | primarily children under 5 (diarrhea) | all, predominantly children (diarrhea) | all, predominantly women and children | all, predominantly children
- Africa vs. Asia vs. Latin America | all | all | Sub-Saharan Africa, Southeast Asia | all | all | all | all | all | all | all
Communicable vs. non-communicable disease | communicable | communicable | communicable | communicable | communicable | Communicable & non-communicable | communicable | communicable | Non- communicable | communicable
One time vs. continuous behavior | continuous | one time | time limited | continuous | one time per episode | continuous | one time per episode | continuous | both (initial adoption and continued use) | one time installation; continuous on part of households to use
Preventative or treatment | prevent | prevent | prevent | prevent | prevent | prevent / treatment | treatment | prevent | prevent | prevent
Delivery source for intervention | either | publicly provided | often publicly provided by NGOs | could be either | could be either | often publicly provided by NGOs | could be either | private decisions | private | public
Resource dimension | low | ? | high | low | low | high | low | low | high | High
Individual vs. Community - level of impact | mostly individual | mostly individual | mostly individual | both | mostly individual | both | mostly individual | both | individual | both
Individual vs. Community - level of intervention | individual | individual | individual | individual | individual | individual/population | individual | individual | individual | community
Urban vs. Rural | rural | rural | urban and rural | urban and rural | urban and rural | urban and rural | urban and rural | urban and rural | both | both, mostly rural