# Abbreviations

3IE: International Initiative for Impact Evaluation
AHRQ: Agency for Healthcare Research and Quality
ARV: antiretrovirals
CHW: Community Health Worker
CPSTF: Community Preventive Services Task Force
EPC: Evidence-based Practice Center
EVIPnet: Evidence Informed Policy Networks
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HASTE: Highest Attainable Standard of Evidence
HDA: Health Development Agency
IC: Implementation Criteria
NHMRC: National Health and Medical Research Council
PMTCT: Prevent Mother-to-Child Transmission
UK NHS: National Health Service
RCTs: Randomized Clinical Trials
SUPPORT: SUPporting Policy relevant Reviews and Trials
SURE: Supporting the Use of Research Evidence
TEP: Technical Expert Panel
USAID: U.S. Agency for International Development